# Appendix D Additional study detail for key question 2

The most relevant data comes from a fair quality retrospective and prospective case series describing cumulative observations on the survival and response to phlebotomy treatment of 251 predominantly male (224/251) patients with hemochromatosis (all with liver biopsies at or after diagnosis to confirm diagnosis) identified in primary care clinics in Germany between 1947 and 1991. ^1^ About one-fifth of cases were identified through family screening (20/251) or incidental biochemical tests (28/251). Excellent follow-up was achieved, with loss of 2/251 patients (0.8%). Earlier publications described results through 1985. ^2,^ ^3^ From 1979 forward, the diagnostic workup and therapy was protocolized to include liver biopsy with quantified liver iron, repeated phlebotomies until iron depletion as indicated by serum ferritin, and then repeat liver biopsy to confirm iron depletion. It is not clear exactly what proportion of the 251 patients were diagnosed from 1979 forward, although a prior publication from the same group identified 163 patients diagnosed through 1983, ^3^ suggesting that the results of this study (particularly the longer-term results) predominantly reflect patients diagnosed and treated before the protocolized approach. Timing for liver biopsy is stated to be at the time of diagnosis in these 163 patients, and this paper further states that the diagnosis of hemochromatosis was suspected from clinical features and biochemical tests and established by liver biopsy with histochemical or chemical analysis of hepatic iron concentration in all patients. ^3^ All patients were treated with phlebotomy to iron depletion, with those after 1979 treated until normal serum ferritin levels were achieved, and iron depletion was confirmed by repeat liver biopsies. Post-treatment biopsies were available for 185 patients (74%), with 34 patients (13.5%) dying before treatment could be completed and the remaining 32 not having completed treatment by the end of the latest study. Cumulative survival for all patients was 93% at 5 years, 77% at 10 years, 62% at 15 years, 55% at 20 years, 46% at 25 years, and 20% at 30 years. Causes of death were not classified as hemochromatosis-related or not. Niederau had excellent follow-up and full ascertainment of cause for all deaths (n=69) during the study with cause of death established by autopsy in 68%, by pre-mortem histology for the 17% of patients with neoplasms, and by clinical reports or accident reports (14%).

At diagnosis, the mean age was 45.7 (SD 10.8) years; 57% (n=142) of patients were cirrhotic (based on liver biopsy interpreted according to generally accepted histological criteria), only 7 of whom were asymptomatic. The proportion that were cirrhotic at diagnosis decreased over time (p ≤ 0.05), from 80% in 1947-1969 to 49% in 1970-1981 and 41% in 1982-1991. Other measures of disease severity showed similar secular declines. Accordingly, cumulative survival also improved over time. Those diagnosed in 1982-1991 showed better survival over about 10 years of follow-up than the two groups diagnosed earlier (log-rank test, p ≤ 0.05) and cumulative survival for HC patients diagnosed in 1982-1991 was not significantly reduced from rates expected for an age-and-sex matched population. Survival differences between subgroups of patients were reported, but are not reliable due to confounding by various factors such as time period of diagnosis, age at diagnosis, sex, excessive alcohol use, and other unmeasured factors such as concomitant hepatitis, dietary factors, etc.

Response to treatment was gauged by comparing pre-post symptoms and clinical features, including level of fibrosis on biopsy, for 185 patients regardless of time of diagnosis. ^1^ Given the secular trends in symptoms and disease severity, the most meaningful data are those based on objective changes in liver biopsies by degree of fibrosis at baseline. Degree of fibrosis was as follows: Stage 0 (pre-fibrosis, non-fibrosis, only septal fibrosis); Stage 1 (not extensive portal fibrosis without bridging septa); Stage 2 (portal fibrosis with briding septa); Stage 3 (annual fibrosis with vascular disruption and cirrhosis). About half of patients with post-treatment repeat liver biopsies (n=93) had stage 3 fibrosis/cirrhosis at diagnosis; 12 (13%) of these improved to stage 2 fibrosis after treatment, none worsened, and 81 (87%) were unchanged. Among patients with stage 2 fibrosis (n=39), about half (n=20) improved to stage 1, none worsened and about half (n=19) were unchanged. Among those with Stage 1 fibrosis (n=32), one-third showed reversal to pre-fibrosis (stage 0), 1 worsened to Stage 2, and 21 (66%) were unchanged. Among those with no fibrosis at baseline (stage 0), most (20/21) were unchanged, while one patient worsened to Stage 1 fibrosis. Very few patients had liver biopsies showing more severe fibrosis after treatment and liver biopsies after treatment were unchanged for most patients, suggesting that treatment arrested disease progression. However, there is no untreated control group with which to compare these findings. For those with some level of liver fibrosis before treatment, 13–50% showed some improvement, with the lowest proportional improvement seen in those with the most advanced liver disease (stage 3), suggesting that treatment is more effective in earlier disease. However, these findings are based on qualitative histological readings and blinding in outcome assessment was not clearly employed.

A fair quality retrospective case series described long-term survival after phlebotomy treatment to iron depletion in 80/90 (89%) of all hereditary hemochromatosis patients diagnosed between 1958 and 1989 in one regional medical center in Canada. ^4^ Patients included probands (56%) and family members (44%). ^4^ Diagnosis was based on clinical history, physical examination, serum ferritin and % transferrin saturation (excluding other conditions associated with iron overload), and confirmed by liver biopsy. About one-third (n=27) presented with cirrhosis and data are not presented as to whether this proportion changed over the observation period. The time period of diagnosis was not controlled for in any analyses. No patients were reported not to have completed treatment except for those who died before treatment was completed.

Seventeen patients (19%) died during follow-up (mean 8.1 +/- 6.8 follow-up years, range 0–31 years). Fourteen of these patients were probands. Eight patients (8.9%) died prior to completing treatment, three of whom died from presumed hemochromatosis-related causes. Overall, about half of all deaths (n=8) were hemochromatosis-related and the other half (n=9) were unrelated. Cumulative survival in hereditary hemochromatosis patients was 87% at 5 years, 81% at 10 years, and 71% at 20 years and was significantly lower at all time points (except under one year and over 14 years) than the cumulative survival of age-and sex-matched provincial controls taken from 1980-1982 life tables. Use of life-tables not corresponding to the entire time period of diagnosis may have exaggerated the reduced survival seen in patients. Cirrhosis (as opposed to those with fibrosis or normal livers) was significantly related to the risk of death in a multivariate Cox regression analysis controlling for disease and age at diagnosis; this analysis did not control for time period of diagnosis.

A fair-poor quality retrospective case series followed 111 patients over who were diagnosed with idiopathic hemochromatosis through routine practice from about 1935 through 1975 in the U.K. ^5^ Survival rates and response to phlebotomy treatment to iron depletion were reported for 85 patients (77%). Diagnosis was established by clinical, biochemical and sometimes histological criteria with secondary iron overload excluded. Liver biopsies were repeated after treatment in 75 patients. Six patients (7%) died before treatment could be completed and another 39 (46%) died after treatment completion (7.7 average years between treatment completion and death). Causes of death were not categorized as hemochromatosis related or not. Cumulative survival after diagnosis for treated patients was 66% at 5 years and 32% at 10 years. Post-treatment liver biopsies showed no histological changes in 68 patients (91%), of whom 56 had cirrhosis and 12 had portal fibrosis, improvement from cirrhosis to portal fibrosis in five patients (7%) and progression from portal fibrosis to cirrhosis in 2 patients (3%). Twelve (16%) accumulated enough iron after treatment to require a repeat course of venesection. The study reported comparisons to untreated historical controls (n=26) but these were excluded due to clear or possible non-comparability between the two groups on numerous features and potential confounding by secular trends in treatment improvements for severe disease such as diabetes mellitus or hepatic failure.

## References for Appendix D

1 Niederau C, Fischer R, Purschel A, Stremmel W, Haussinger D, Strohmeyer G. Long-term survival in patients with hereditary hemochromatosis. Gastroenterology. 1996;110(4):1107-19. [pmid: 8613000].
2 Niederau C, Fischer R, Sonnenberg A, Stremmel W, Trampisch HJ, Strohmeyer G. Survival and causes of death in cirrhotic and in noncirrhotic patients with primary hemochromatosis. New England Journal of Medicine. 1985;313(20):1256-62. [pmid: 4058506].
3 Strohmeyer G, Niederau C, Stremmel W. Survival and causes of death in hemochromatosis. Observations in 163 patients. Annals of the New York Academy of Sciences. 1988;526:245-57. [pmid: 3389643].
4 Adams PC, Speechley M, Kertesz AE. Long-term survival analysis in hereditary hemochromatosis. Gastroenterology. 1991;101(2):368-72. [pmid: 2065912].
5 Bomford A, Williams R. Long term results of venesection therapy in idiopathic haemochromatosis. Quarterly Journal of Medicine. 1976;45(180):611-23. [pmid: 188063].

## Table 1: Therapeutic phlebotomy studies

Table 1 Therapeutic phlebotomy studies

## Table 2. Studies excluded from key question 2

### Study Citation Reason for exclusion

Adams PC, Kertesz AE, Valberg LS. Rate of iron reaccumulation following iron depletion in hereditary hemochromatosis. Implications for venesection therapy. Journal of Clinical Gastroenterology. 1993;16(3):207-10. Does not present relevant outcomes. [pmid: 8505491].
Adams PC. Factors affecting the rate of iron mobilization during venesection therapy for genetic hemochromatosis. American Journal of Hematology. 1998;58(1):16-9. Does not present relevant outcomes. [pmid: 9590143].
Askari AD, Muir WA, Rosner IA, Moskowitz RW, McLaren GD, Braun WE. Arthritis of hemochromatosis. Clinical spectrum, relation to histocompatibility antigens, and effectiveness of early phlebotomy. American Journal of Medicine. 1983;75(6):957-65. Quality. [pmid: 6650551].
Barton JC, Bottomley SS. Iron deficiency due to excessive therapeutic phlebotomy in hemochromatosis. American Journal of Hematology. 2000;65(3):223-6. < 20 patients. [pmid: 11074539].
Batey RG, Hussein S, Sherlock S, Hoffbrand AV. The role of serum ferritin in the management of idiopathic haemochromatosis. Scandinavian Journal of Gastroenterology. 1978;13(8):953-7. Does not present relevant outcomes. [pmid: 725519].
Bodemann HH, Tanzi-Fetta RF, Schroter-Urban H, Volk BA, Keul J, Lohr GW. Ferritin in erythrocytes and plasma of patients with iron overload. Blut. 1985;51(1):25-31. Quality. [pmid: 3848335].
Candell-Riera J, Lu L, Seres L, Gonzalez JB, Batlle J, Permanyer-Miralda G, et al. Cardiac hemochromatosis: beneficial effects of iron removal therapy. An echocardiographic study. American Journal of Cardiology. 1983;52(7):824-9. Quality. [pmid: 6624673].
Cesana M, Mandelli C, Tiribelli C, Bianchi PA, Conte D. Concomitant primary hemochromatosis and beta-thalassemia trait: iron depletion by erythrocytapheresis and desferrioxamine. American Journal of Gastroenterology. 1989;84(2):150-2. < 20 patients. [pmid: 2916524].
Chow LH, Frei JV, Hodsman AB, Valberg LS. Low serum 25-hydroxyvitamin D in hereditary hemochromatosis: relation to iron status. Gastroenterology. 1985;88(4):865-9. Quality. [pmid: 3838288].
Cleton MI, de Bruijn WC, van Blokland WT, Marx JJ, Roelofs JM, Rademakers LH. Iron content and acid phosphatase activity in hepatic parenchymal lysosomes of patients with hemochromatosis before and after phlebotomy treatment. Ultrastructural Pathology. 1988;12(2):161-74. Apr. < 20 patients. [pmid: 3363682].
Cleton MI, Roelofs JM, Blok-Van Hoek CJ, de Bruijn WC. Integrated image and X-ray microanalysis of hepatic lysosomes in a patient with idiopathic hemosiderosis before and after treatment by phlebotomy. Scanning Electron Microscopy (Pt 3):999–1006, 1986. < 20 patients
Conte D, Mandelli C, Cesana M, Ferrini R, Marconi M, Bianchi A. Effectiveness of erythrocytapheresis in idiopathic hemochromatosis. Report of 14 cases. International Journal of Artificial Organs. 1989;12(1):59-62. Does not report relevant outcomes. [pmid: 2925263].
Conte D, Piperno A, Mandelli C, Fargion S, Cesana M, Brunelli L, et al. Clinical, biochemical and histological features of primary haemochromatosis: a report of 67 cases. Liver. 1986;6(5):310-5. Quality. [pmid: 3023781].
Cundy T, Butler J, Bomford A, Williams R. Reversibility of hypogonadotrophic hypogonadism associated with genetic haemochromatosis. Clinical Endocrinology. 1993;38(6):617-20. < 20 patients. [pmid: 8334747].
Dabestani A, Child JS, Henze E, Perloff JK, Schon H, Figueroa WG, et al. Primary hemochromatosis: anatomic and physiologic characteristics of the cardiac ventricles and their response to phlebotomy. American Journal of Cardiology. 1984;54(1):153-9. < 20 patients. [pmid: 6741807].
Dymock IW, Cassar J, Pyke DA, Oakley WG, Williams R. Observations on the pathogenesis, complications and treatment of diabetes in 115 cases of haemochromatosis. American Journal of Medicine. 1972;52(2):203-10. Quality. [pmid: 5058506].
Easley RM Jr, Schreiner BF Jr, Yu PN. Reversible cardiomyopathy associated with hemochromatosis. New England Journal of Medicine. 1972;287(17):866-7. < 20 patients. [pmid: 5071966].
Failla M, Giannattasio C, Piperno A, Vergani A, Grappiolo A, Gentile G, et al. Radial artery wall alterations in genetic hemochromatosis before and after iron depletion therapy. Hepatology. 2000;32(3):569-73. < 20 patients. [pmid: 10960451].
Fargion S, Mandelli C, Piperno A, Cesana B, Fracanzani AL, Fraquelli M, Bianchi PA, Fiorelli G, Conte D. Survival and prognostic factors in 212 Italian patients with genetic hemochromatosis. Hepatology. 1992;15(4):655-9. Quality. [pmid: 1312985].
Feely J, Counihan TB. Haemochromatosis presenting as angina and responding to venesection. British Medical Journal. 1977;2(6088):681-2. < 20 patients. [pmid: 902053].
Fellows IW, Stewart M, Jeffcoate WJ, Smith PG, Toghill PJ. Hepatocellular carcinoma in primary haemochromatosis in the absence of cirrhosis. Gut. 1988;29(11):1603-6. < 20 patients. [pmid: 2850272].
Fracanzani AL, Fargion S, Romano R, Conte D, Piperno A, D'Alba R, et al. Portal hypertension and iron depletion in patients with genetic hemochromatosis. Hepatology. 1995;22(4 Pt 1):1127-31. Quality. [pmid: 7557861].
Gama R, Smith MJ, Wright J, Marks V. Hypopituitarism in primary haemochromatosis; recovery after iron depletion. Postgraduate Medical Journal. 1995;71(835):297-8. < 20 patients. [pmid: 7596937].
Goh J, Callagy G, McEntee G, O'Keane JC, Bomford A, Crowe J. Hepatocellular carcinoma arising in the absence of cirrhosis in genetic haemochromatosis: three case reports and review of literature. European Journal of Gastroenterology & Hepatology. 1999;11(8):915-9. < 20 patients. [pmid: 10514128].
Grima KM. Therapeutic apheresis in hematological and oncological diseases. Journal of Clinical Apheresis. 2000;15(12):28-52. Review article. [pmid: 10767050].
Guillygomarc'h A, Mendler MH, Moirand R, Laine F, Quentin V, David V, Brissot P, Deugnier Y. Venesection therapy of insulin resistance-associated hepatic iron overload. Journal of Hepatology. 2001;35(3):344-9. Wrong population. [pmid: 11592595].
Hash RB. Hereditary hemochromatosis. Journal of the American Board of Family Practice. 2001;14(4):266-73. Aug. Review article. [pmid: 11458969].
Hines C Jr, Davis WD Jr, Ferrante WA. Hepatoma developing in hemochromatosis in spite of adequate treatment by multiple phlebotomies. American Journal of Digestive Diseases. 1971;16(4):349-55. Case report. [pmid: 4324431].
Hramiak IM, Finegood DT, Adams PC. Factors affecting glucose tolerance in hereditary hemochromatosis. Clinical & Investigative Medicine - Medecine Clinique et Experimentale 1920;(2):110–118. Quality
Hultcrantz R, Angelin B, Bjorn-Rasmussen E, Ewerth S, Einarsson K. Biliary excretion of iron and ferritin in idiopathic hemochromatosis. Gastroenterology. 1989;96(6):1539-45. Quality. [pmid: 2714579].
Jakeman A, Thompson T, McHattie J, Lehotay DC. Sensitive method for nontransferrin-bound iron quantification by graphite furnace atomic absorption spectrometry. Clinical Biochemistry. 2001;34(1):43-7. < 20 patients. [pmid: 11239514].
Kaltwasser JP, Werner E, Schalk K, Hansen C, Gottschalk R, Seidl C. Clinical trial on the effect of regular tea drinking on iron accumulation in genetic haemochromatosis. Gut. 1998;43(5):699-704. Quality. [pmid: 9824354].
Kelly TM, Edwards CQ, Meikle AW, Kushner JP. Hypogonadism in hemochromatosis: reversal with iron depletion. Annals of Internal Medicine. 1984;101(5):629-32. Does not present relevant outcomes. [pmid: 6435491].
Kohan A, Niborski R, Daruich J, Rey J, Bastos F, Amerise G, Herrera R, Garcia M, Olivera W, Santarelli MT, Avalos JS, Findor J. Erythrocytapheresis with recombinant human erythropoietin in hereditary hemochromatosis therapy: a new alternative. VoxSanguinis. 2000;79(1):40-5. < 20 patients.
Leitman SF, Browning JN, Yau YY, Mason G, Klein HG, Conry-Cantilena C, et al. Hemochromatosis subjects as allogeneic blood donors: a prospective study. Transfusion. 2003;43(11):1538-44. Does not report relevant outcomes. [pmid: 14617312].
Limdi JK, Crampton JR. Hereditary haemochromatosis. Qjm. 2004;97(6):315-24. Review article. [pmid: 15152104].
Lombard M, Bomford A, Hynes M, Naoumov NV, Roberts S, Crowe J, et al. Regulation of the hepatic transferrin receptor in hereditary hemochromatosis. Hepatology. 1989;9(1):1-5. Does not present relevant outcomes. [pmid: 2642288].
Lufkin EG, Baldus WP, Bergstralh EJ, Kao PC. Influence of phlebotomy treatment on abnormal hypothalamic-pituitary function in genetic hemochromatosis. Mayo Clinic Proceedings. 1987;62(6):473-9. Quality. [pmid: 3106726].
Mainous AG III, Wells B, Carek PJ, Gill JM, Geesey ME. The mortality risk of elevated serum transferrin saturation and consumption of dietary iron. Annals of Family Medicine. 2004;2(2):139-44. Apr. No phlebotomy treatment. [pmid: 15083854].
Mandelli C, Cesarini L, Piperno A, Fargion S, Fracanzani AL, Barisani D, et al. Saturability of hepatic iron deposits in genetic hemochromatosis. Hepatology. 1992;16(4):956-9. Does not present relevant outcomes. [pmid: 1398502].
McDonnell SM, Witte DL, Cogswell ME, McIntyre R. Strategies to increase detection of hemochromatosis. Annals of Internal Medicine. 1998;129(11):987-92. Review article. [pmid: 9867752].
Milman N, Pedersen P, Steig T, Byg KE, Graudal N, Fenger K. Clinically overt hereditary hemochromatosis in Denmark 1948-1985: epidemiology, factors of significance for long-term survival, and causes of death in 179 patients. Annals of Hematology. 2001;80(12):737-44. Quality. [pmid: 11797115].
Milman N. Hereditary haemochromatosis in Denmark 1950-1985. Clinical, biochemical and histological features in 179 patients and 13 preclinical cases. Danish Medical Bulletin. 1991;38(4):385-93. Does not report relevant outcomes. [pmid: 1914539].
Moirand R, Adams PC, Bicheler V, Brissot P, Deugnier Y. Clinical features of genetic hemochromatosis in women compared with men. Annals of Internal Medicine. 1997;127(2):105-10. Does not report relevant outcomes. [pmid: 9229998].
Morcos M, Dubois S, Bralet MP, Belghiti J, Degott C, Terris B. Primary liver carcinoma in genetic hemochromatosis reveals a broad histologic spectrum. American Journal of Clinical Pathology. 2001;116(5):738-43. Does not report relevant outcomes. [pmid: 11710692].
Muncunill J, Vaquer P, Galmes A, Obrador A, Parera M, Bargay J, Besalduch J. In hereditary hemochromatosis, red cell apheresis removes excess iron twice as fast as manual whole blood phlebotomy. Journal of Clinical Apheresis. 2002;17(2):88-92. < 20 patients. [pmid: 12210712].
Muting D, Kalk JF, Fischer R, Wiewel D. Spontaneous regression of oesophageal varices after long-term conservative treatment. Retrospective study in 20 patients with alcoholic liver cirrhosis, posthepatitic cirrhosis and haemochromatosis with cirrhosis. Journal of Hepatology. 1990;10(2):158-62. Not phlebotomy treatment. [pmid: 2332585].
Niederau C, Stremmel W, Strohmeyer GW. Clinical spectrum and management of haemochromatosis. Baillieres Clinical Haematology. 1994;7(4):881-901. Review article. [pmid: 7881158].
Niederau C, Strohmeyer G, Stremmel W. Epidemiology, clinical spectrum and prognosis of hemochromatosis. Advances in Experimental Medicine & Biology. 1994;356:293-302. Review article. [pmid: 7887234].
Olsson KS, Ritter B, Lundin PM. Liver affection in iron overload studied with serum ferritin and serum aminotransferases. Acta Medica Scandinavica. 1985;217(1):79-84. Quality. [pmid: 3976436].
Piperno A, Vergani A, Salvioni A, Trombini P, Vigano M, Riva A, et al. Effects of venesections and restricted diet in patients with the insulin-resistance hepatic iron overload syndrome. Liver International. 2004;24(5):471-6. Does not report relevant outcomes. [pmid: 15482345].
Propper R, Nathan D. Clinical removal of iron. Annual Review of Medicine. 1982;33:509-19. Clinical review article.
Prunescu CC, Prunescu P, Vilcu AL. Ultrastructure of the liver in idiopathic haemosiderosis and results of a treatment by repeated bleedings. Morphologie et Embryologie. 1987;33(2):133-6. Jun. Case report. [pmid: 2956507].
Riquelme A, Soza A, Nazal L, Martinez G, Kolbach M, Patillo A, et al. Histological resolution of steatohepatitis after iron depletion. Digestive Diseases & Sciences. 2004;49(6):1012-5. Case report. [pmid: 15309893].
Sargent T, Saito H, Winchell HS. Iron absorption in hemochromatosis before and after phlebotomy therapy. Journal of Nuclear Medicine. 1971;12(10):660-7. Does not report relevant outcomes. [pmid: 5000107].
Seamark CJ, Hutchinson M. Controversy in primary care: Should asymptomatic haemochromatosis be treated?. BMJ. 2000;320(7245):1314-7. Case report. [pmid: 10807626].
Sigal SH, Fleischner GM, Weiner FR. Hypogonadal-induced anemia in genetic hemochromatosis: implications for phlebotomy therapy. American Journal of Gastroenterology. 1995;90(1):152-3. Case report. [pmid: 7801923].
Spellberg MA. Treatment of hemochromatosis. American Journal of Gastroenterology. 1969;51(6):516-22. Review article. [pmid: 4894612].
Tiniakos G, Williams R. Cirrhotic process, liver cell carcinoma and extrahepatic malignant tumors in idiopathic haemochromatosis. Study of 71 patients treated with venesection therapy. Applied Pathology. 1988;6(2):128-38. Quality. [pmid: 2839215].
Weintraub LR, Conrad ME, Crosby WH. The treatment of hemochromatosis by phlebotomy. Medical Clinics of North America. 1966;50(6):1579-90. < 20 patients. [pmid: 5339192].
Wojcik JP, Speechley MR, Kertesz AE, Chakrabarti S, Adams PC. Natural history of C282Y homozygotes for hemochromatosis. Canadian Journal of Gastroenterology. 2002;16(5):297-302. Does not report relevant outcomes. [pmid: 12045778].