# Appendix C

Table 1 Genotype screening studies in various populations

Study | Population | C282Y:C282Y frequency | TF saturation* (initial test unless stated) | Serum ferritin* | Iron overload | Diabetes | Elevated liver enzymes | Hepatic fibrosis or cirrhosis
Health clinics
Beutler 2002a ^33^ ; Beutler 2002b ^55^ , Beutler 2000 ^54^ , Waalen 2002 ^58^ | KP San Diego n = 41,038 Mean age: 57 y Non-Hispanic Caucasian: 77% 140 C282YY from KP San Diego screening study | 152/41,038 3.7/1000 | >50: 75% M 40% F Elev overall: 57% After excluding frequent blood donors: 76% M, 41% F | >250 M: 76% >200 F: 54% Elev overall: 65% After excluding frequent blood donors: 77% M, 56% F | NR 102 eligible (not prev treated) 54 completed treatment 13/54 (24%) had >5 g iron removed | C282YY: 5.6% Non-C282YY: 8.4% | AST > 40 C282YY: 8.2% Non-C282YY: 3.8% | NR
Deugnier 2002 ^56^ | Brittany, France n = 9396 35.8% male (deliberately weighted to include younger males) | 54/9396 5.7/1000 | >55 M: 80% >50 F: 41% Elev overall: 48% | >280 M: 70% >130 F: 33% Elev overall: 40% | NR | M C282YY: 0% M non-C282YY: 0.8% F C282YY: 2.3% F non-C282YY: 0.9% | ALT>70 M C282YY: 10% M Non-C282YY: 5% M ALT > 35 F C282YY: 5% F Non-C282YY: 5% F
Phatak 2002** ^57^ | Rochester NY n = 4865 randomly selected Mean age: 52 y 42% male 66% Caucasian | 12 of 4865 2.5/1000 | >45: 75% M,100% F >50: 75% M, 88% F >45 Overall: 92% >50 Overall: 83% | >200: 100% M, 50% F, Overall 67% >300: 50% M, 37.5% F, Overall 41% | 4/5 receiving TP had > 4g removed. 4/4 biopsied had HIO (criteria not given) At least 4/12 had HIO and possibly 8/12-not sure | 0/12 = 0% | NR | Cirrhosis: 0% of 4 biopsied
Blood donor populations
Adams 2000 ^59^ | Canadian blood donors n = 5211 56.7% male 96% full European ancestry | 16/5211 3.1/1000 | > 50 X 2 M: 3/5 (60%) > 45 X 2 F: 3/11 (27%) Combined: 6/16 (38%) | >300 M: 40% >200 F: 9% Overall: 18.8% | NR | 0/16 or 0% | Elev AST (ND): 0/16 or 0% Elev ALT (ND): 0/16 or 0% | NR
Chambers 2003 ^61^ | Male English blood donors who donated < 4 units previously n = 6261 Mean age = 39 y | 18/6261 2.8/1000 | > 50: 78% | >250: 56% >500: 11% | NR | NR | NR | NR
Sanchez 2003 ^60^ | Barcelona, Spain n = 5370 blood donors 64% Male Mean age: 28 y | 8 of 5370 1.5/1000 | >50 on 1st: 80% M, 67% F | > 300: 80% M, 0% F | > 4 g removed: 2/3 (67%) of those with phlebotomy 25% of C282YY | NR | NR | NR
Population screening
Olynyk 1999 ^62^ | Busselton Australia n = 3011 randomly selected 50% Male Predom white Age range: 20 – 79 y | 16/3011 5.3/1000 4/16 prev diagnosed 12 new C282YY (5.3/1000) | >45: 93.8% 2nd > 45: 93.8% | >300: 50% >300 untreated: 58.3% | Liver biopsy: 58% 7/12 HII>1.9: 4/7 (57.1%) of those biopsied 33% of C282YY HIC> 20 μmol/g dry: 100% of those biopsied (7/7) 58% C282YY | NR | NR | Fibrosis: 29%of biopsied (2/7) Cirrhosis: 14% of biopsied (1/7)(also had history alcohol >60 g/day) No Controls
Voter Rolls
Burt, 1998 ^63^ | 1064 voters New Zealand Mean age: 50 y 39.8% Male | 5/1064 4.7/1000 | > 55: 100% | 2nd SF >300 M: 100% >160 F: 50% Overall elev: 60% | Liver biopsy: 60% HII>1.9: 3/3 (100%) selected C282YY 3/5 (60%) all C282YY Grade 3–4: 33% of those biopsied 20% of all C282YY | NR | NR | NR
Employment screening
Distante 1999 ^64^ | 505 hospital employees in Oslo Norway 79% Female Mean age: 38 y | 2/505 4/1000 | > 50: 100% | > 200: 100% | TP on 50%: 5.2 g removed 1/1 IO by TP HIC: 47μmol Biopsy 0/1 IO: 50% selected C282YY Total IO = 100% | NR | NR | NR
McDonnell 1999 ^65^ | 1450 HMO employees in Springfield,MO 83% women 98% white Mean age:41 y | 6/1450 4.1/1000 | >50 × 2 F >60 × 2 M Overall elev: 67% of C282YY | >95%ile for age and sex: 50% C282YY | HII = 2.2: 1/1 by biopsy 1/2 by TP 2/3 (67%) selected C282YY 2/6 (33%) all C282YY | NR | NR | Fibrosis: 0/1 (0%) Cirrhosis: 0/1 (0%)
Delatycki 2005 ^66^ | 11,307 workplace employees in Australia 47% male 63% N. European | 51/11,307 4 previous diagnosed 4.5/1000 47 new C282YY | Criteria for elevation not given, 65% were “elevated” | NR | 6 recommended 4 biopsied | NR | NR | Fibrosis 2/4 biopsied 50% selected C282YY, 2/47 (4.3%) all C282YY
Family studies
Barton 1999 ^67^ | 150 relatives of 61 probands in Alabama 100% Caucasian 52% female Mean age: 46 y 1 pt <18, was C282YY | 25/149 161/1000 | >50 F × 2 >60 M × 2 Overall: 87.5% | >300 M >200 F Overall 96% elev | NR | 16% | NR | 2/25 (8%)
Adams 1998** ^68^ | 51 C282YY relatives of probands 70% male Mean age M: 52 y Mean age F: 57 y | Not able to calculate | >55: 33/38 (87%) M 11/13 (92%) F | >300 M: 34/38 (89%) >200 F: 12/13 (92%) | >5 g: 9/23 (39%) M 3/5 (60%) F All : 12/51(24%) HII > 1.9: 19/22 (86%) M 6/7 (86%) F All : 25/51 (49%)

* In homozygotes

** Data not included in summary estimates table

Elev-elevated; F-female; M-male; C282YY-C282Y/C282Y; AST-aspartate aminotransferase; ND-not determined; HII-hepatic iron index; HIC-hepatic iron content; SF-serum ferritin; TP-therapeutic phlebotomy; IO-iron overload

## Table 2. Studies excluded from key question 1

### Study Citation Reason for exclusion

Iron overload disorders among Hispanics—San Diego, California, 1995. MMWR - Morbidity & Mortality Weekly Report 45(45):991–3, 1996. Study disease definition does not meet our definition of asymptomatic primary iron overload or clinical disease.
A simple genetic test identifies 90% of UK patients with haemochromatosis. The UK Haemochromatosis Consortium. Gut 41(6):841–4, 1997. Not a screening population
Adams PC, Reboussin DM, Barton JC, McLaren CE, Eckfeldt JH, McLaren GD, Dawkins FW, Acton RT, Harris EL, Gordeuk VR, Leiendecker-Foster C, Speechley M, Snively BM, Holup JL, Thomson E, Sholinsky P. Hemochromatosis and Iron Overload Screening (HEIRS) Study Research Investigators. Hemochromatosis and iron-overload screening in a racially diverse population. New England Journal of Medicine. 2005;352(17):1769-78. Does not report relevant outcomes. [pmid: 15858186].
Adams PC. Is there a threshold of hepatic iron concentration that leads to cirrhosis in C282Y hemochromatosis?. American Journal of Gastroenterology. 2001;96(2):567-9. Not a screening population. [pmid: 11232708].
Adams PC, Deugnier Y, Moirand R, Brissot P. The relationship between iron overload, clinical symptoms, and age in 410 patients with genetic hemochromatosis. Hepatology. 1997;25(1):162-6. Not a screening population. [pmid: 8985284].
Adams PC, Gregor JC, Kertesz AE, Valberg LS. Screening blood donors for hereditary hemochromatosis: decision analysis model based on a 30-year database. Gastroenterology. 1995;109(1):177-88. Does not contain primary data. [pmid: 7797016].
Adams PC, Kertesz AE, Valberg LS. Clinical presentation of hemochromatosis: a changing scene. American Journal of Medicine. 1991;90(4):445-9. Not a screening population. [pmid: 2012084].
Adams PC, Speechley M, Kertesz AE. Long-term survival analysis in hereditary hemochromatosis. Gastroenterology. 1991;101(2):368-72. Not a screening population. [pmid: 2065912].
Adams PC. Hepatic iron in hemochromatosis. Digestive Diseases & Sciences. 1990;35(6):690-2. Includes data from patients < 18 yrs. [pmid: 2344801].
Ammann RW, Muller E, Bansky J, Schuler G, Hacki WH. High incidence of extrahepatic carcinomas in idiopathic hemochromatosis. Scandinavian Journal of Gastroenterology. 1980;15(6):733-6. Not a screening population. [pmid: 6259710].
Asberg A, Hveem K, Kruger O, Bjerve KS. Persons with screening-detected haemochromatosis: as healthy as the general population?. Scandinavian Journal of Gastroenterology. 2002;37(6):719-24. Study disease definition does not meet our definition of asymptomatic primary iron overload or clinical disease. [pmid: 12126253].
Asberg A, Hveem K, Thorstensen K, Ellekjter E, Kannelonning K, Fjosne U, Halvorsen TB, Smethurst HB, Sagen E, Bjerve KS. Screening for hemochromatosis: high prevalence and low morbidity in an unselected population of 65,238 persons. Scandinavian Journal of Gastroenterology. 2001;36(10):1108-1115. Does not include C282Y genotyping in screening sequence. [pmid: 11589387].
Askari AD, Muir WA, Rosner IA, Moskowitz RW, McLaren GD, Braun WE. Arthritis of hemochromatosis. Clinical spectrum, relation to histocompatibility antigens, and effectiveness of early phlebotomy. American Journal of Medicine. 1983;75(6):957-65. Not a screening population. [pmid: 6650551].
Assy N, Adams PC. Predictive value of family history in diagnosis of hereditary hemochromatosis. Digestive Diseases & Sciences. 1997;42(6):1312-5. Study design. [pmid: 9201100].
Bacon BR, Sadiq SA. Hereditary hemochromatosis: presentation and diagnosis in the 1990s. American Journal of Gastroenterology. 1997;92(5):784-9. Not a screening population. [pmid: 9149185].
Baer DM, Simons JL, Staples RL, Rumore GJ, Morton CJ. Hemochromatosis screening in asymptomatic ambulatory men 30 years of age and older. American Journal of Medicine. 1995;98(5):464-468. Does not include C282Y genotyping in screening sequence. [pmid: 7733125].
Balan V, Baldus W, Fairbanks V, Michels V, Burritt M, Klee G. Screening for hemochromatosis: a cost-effectiveness study based on 12,258 patients. Gastroenterology. 1994;107(2):453-459. Does not include C282Y genotyping in screening sequence. [pmid: 8039622].
Barosi G, Salvaneschi L, Grasso M, Martinetti M, Marchetti M, Bodini U, et al. High prevalence of a screening-detected, HFE-unrelated, mild idiopathic iron overload in Northern Italy. Haematologica. 2002;87(5):472-8. Does not report relevant outcomes. [pmid: 12010659].
Barton JC, Cheatwood SM, Key TJ, Acton RT. Hemochromatosis detection in a health screening program at an Alabama forest products mill. Journal of Occupational & Environmental Medicine. 2002;44(8):745-51. Does not report relevant outcomes. [pmid: 12185795].
Barton JC, Barton NH, Alford TJ. Diagnosis of hemochromatosis probands in a community hospital. American Journal of Medicine. 1997;103(6):498-503. Not a screening population. [pmid: 9428833].
Barton CJ, Shih WW, Sawada-Hirai R, Acton RT, Harmon L, Rivers C, Rothenberg BE. Genetic and clinical description of hemochromatosis probands and heterozygotes: evidence that multiple genes linked to the major histocompatibility complex are responsible for hemochromatosis. Blood Cells Molecules & Diseases. discussion 145a.–b. 1997;23(1):135-45. Not a screening population.
Bassett ML, Halliday JW, Ferris RA, Powell LW. Diagnosis of hemochromatosis in young subjects: predictive accuracy of biochemical screening tests. Gastroenterology. 1984;87(3):628-33. < 18 yrs included. [pmid: 6745616].
Bassett ML, Halliday JW, Powell LW. Value of hepatic iron measurements in early hemochromatosis and determination of the critical iron level associated with fibrosis. Hepatology. Feb. 1986;6(1):24-9. Does not report relevant outcomes. [pmid: 3943787].
Bell H, Thordal C, Raknerud N, Hansen T, Bosnes V, Halvorsen R, Heier HE, Try K, Leivestad T, Thomassen Y. Prevalence of hemochromatosis among first-time and repeat blood donors in Norway. Journal of Hepatology. 1997;26(2):272-279. Does not include C282Y genotyping in screening sequence. [pmid: 9059946].
Bell H, Berg JP, Undlien DE, Distante S, Raknerud N, Heier HE, Try K, Thomassen Y, Haug E, Raha-Chowdhury R, Thorsby E. The clinical expression of hemochromatosis in Oslo, Norway. Excessive oral iron intake may lead to secondary hemochromatosis even in HFE C282Y mutation negative subjects. Scandinavian Journal of Gastroenterology. 2000;35(12):1301-7. Not a screening population. [pmid: 11199371].
Borwein ST, Ghent CN, Flanagan PR, Chamberlain MJ, Valberg LS. Genetic and phenotypic expression of hemochromatosis in Canadians. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 1983;6(3):171-9. Does not report relevant outcomes. [pmid: 6652983].
Bradbear RA, Bain C, Siskind V, Schofield FD, Webb S, Axelsen EM, et al. Cohort study of internal malignancy in genetic hemochromatosis and other chronic nonalcoholic liver diseases. Journal of the National Cancer Institute. 1985;75(1):81-4. Not a screening population. [pmid: 2989605].
Bradley LA, Haddow JE, Palomaki GE. Population screening for haemochromatosis: a unifying analysis of published intervention trials. Journal of Medical Screening. 1996;3(4):178-84. Review article. [pmid: 9041481].
Bulaj ZJ, Ajioka RS, Phillips JD, LaSalle BA, Jorde LB, Griffen LM, Edwards CQ, Kushner JP. Disease-related conditions in relatives of patients with hemochromatosis. New England Journal of Medicine. 2000;343(21):1529-35. Quality. [pmid: 11087882].
Buysschaert M, Paris I, Selvais P, Hermans MP. Clinical aspects of diabetes secondary to idiopathic haemochromatosis in French-speaking Belgium. Diabetes & Metabolism. 1997;23(4):308-13. Case series. [pmid: 9342544].
Cadet E, Capron D, Gallet M, Omanga-Leke ML, Boutignon H, Julier C, Robson KJ, Rochette J. Reverse cascade screening of newborns for hereditary haemochromatosis: a model for other late onset diseases?. Journal of Medical Genetics. 2005;42(5):390-5. Includes data from patients < 18 yrs Cannot separate C282Y homozygotes from C282Y heterozygotes. [pmid: 15863667].
Cartwright GE, Edwards CQ, Kravitz K, Skolnick M, Amos DB, Johnson A, et al. Hereditary hemochromatosis. Phenotypic expression of the disease. New England Journal of Medicine. 1979;301(4):175-9. Does not report relevant outcomes. [pmid: 449974].
Cecchetti G, Binda A, Piperno A, Nador F, Fargion S, Fiorelli G. Cardiac alterations in 36 consecutive patients with idiopathic haemochromatosis: polygraphic and echocardiographic evaluation. European Heart Journal. 1991;12(2):224-30. Not a screening population. [pmid: 2044557].
Cogswell ME, Gallagher ML, Steinberg KK, Caudill SP, Looker AC, Bowman BA, et al. HFE genotype and transferrin saturation in the United States. Genetics in Medicine. 2003;5(4):304-10. Aug. Study disease definition does not meet our definition of asymptomatic primary iron overload or clinical disease. [pmid: 12865759].
Crawford DH, Jazwinska EC, Cullen LM, Powell LW. Expression of HLA-linked hemochromatosis in subjects homozygous or heterozygous for the C282Y mutation. Gastroenterology. 1998;114(5):1003-8. Not a screening population. [pmid: 9558290].
Cundy T, Bomford A, Butler J, Wheeler M, Williams R. Hypogonadism and sexual dysfunction in hemochromatosis: the effects of cirrhosis and diabetes. Journal of Clinical Endocrinology & Metabolism. 1989;69(1):110-6. Not a screening population. [pmid: 2732293].
Deugnier YM, Charalambous P, le Quilleuc D, Turlin B, Searle J, Brissot P, et al. Preneoplastic significance of hepatic iron-free foci in genetic hemochromatosis: a study of 185 patients. Hepatology. 1993;18(6):1363-9. Not a screening population. [pmid: 7902316].
Distante S, Berg JP, Lande K, Haug E, Bell H. HFE gene mutation (C282Y) and phenotypic expression among a hospitalised population in a high prevalence area of haemochromatosis. Gut. 2000;47(4):575-9. Inconsistent application of exclusion criteria. [pmid: 10986220].
Edwards CQ, Griffen LM, Kushner JP. The morbidity of hemochromatosis among clinically unselected homozygotes: preliminary report. Advances in Experimental Medicine & Biology. 1994;356:303-8. Does not report relevant outcomes. [pmid: 7887235].
Edwards CQ, Griffen LM, Kushner JP. Comparison of stainable liver iron between symptomatic and asymptomatic hemochromatosis homozygotes and their homozygous relatives. American Journal of the Medical Sciences. 1991;301(1):44-6. Not a screening population. [pmid: 1994729].
Edwards CQ, Griffen LM, Goldgar D, Drummond C, Skolnick MH, Kushner JP. Prevalence of hemochromatosis among 11,065 presumably healthy blood donors. New England Journal of Medicine. 1988;318(21):1355-1362. Does not include C282Y genotyping in screening sequence. [pmid: 3367936].
Edwards CQ, Cartwright GE, Skolnick MH, Amos DB. Homozygosity for hemochromatosis: clinical manifestations. Annals of Internal Medicine. 1980;93(4):519-25. Does not report relevant outcomes. [pmid: 7436183].
Elliott R, Lin BP, Dent OF, Tait A, Smith CI. Prevalence of hemochromatosis in a random sample of asymptomatic men. Australian and New Zealand Journal of Medicine. 1986;16(4):491-495. Does not include C282Y genotyping in screening sequence. [pmid: 3467692].
Elmberg M, Hultcrantz R, Ekbom A, Brandt L, Olsson S, Olsson R, et al. Cancer risk in patients with hereditary hemochromatosis and in their first-degree relatives. Gastroenterology. 2003;125(6):1733-41. Not a screened population. [pmid: 14724826].
Fargion S, Fracanzani AL, Piperno A, Braga M, D'Alba R, Ronchi G et al. Prognostic factors for hepatocellular carcinoma in genetic hemochromatosis. Hepatology 1994;(6):1426–1431. Not a screening population
Fargion S, Mandelli C, Piperno A, Cesana B, Fracanzani AL, Fraquelli M, et al. Survival and prognostic factors in 212 Italian patients with genetic hemochromatosis. Hepatology. 1992;15(4):655-9. Not a screening population. [pmid: 1312985].
Fiel MI, Schiano TD, Bodenheimer HC, Thung SN, King TW, Varma CR, et al. Hereditary hemochromatosis in liver transplantation. Liver Transplantation & Surgery. 1999;5(1):50-6. Not a screening population. [pmid: 9873093].
Fleming DJ, Jacques PF, Tucker KL, Massaro JM, D'Agostino RB Sr, Wilson PW, et al. Iron status of the free-living, elderly Framingham Heart Study cohort: an iron-replete population with a high prevalence of elevated iron stores. American Journal of Clinical Nutrition. 2001;73(3):638-46. Does not report relevant outcomes. [pmid: 11237943].
Fletcher LM, Dixon JL, Purdie DM, Powell LW, Crawford DH. Excess alcohol greatly increases the prevalence of cirrhosis in hereditary hemochromatosis. Gastroenterology. 2002;122(2):281-9. Not a screening population. [pmid: 11832443].
Fox CJ, Cullen DJ, Knuiman MW, Cumpston GN, Divitini ML, Rossi E, et al. Effects of body iron stores and haemochromatosis genotypes on coronary heart disease outcomes in the Busselton health study. Journal of Cardiovascular Risk. 2002;9(5):287-93. Study disease definition does not meet our definition of asymptomatic primary iron overload or clinical disease. [pmid: 12394323].
Fracanzani AL, Conte D, Fraquelli M, Taioli E, Mattioli M, Losco A, et al. Increased cancer risk in a cohort of 230 patients with hereditary hemochromatosis in comparison to matched control patients with non-iron-related chronic liver disease. Hepatology. 2001;33(3):647-51. Not a screening population. [pmid: 11230745].
Fracanzani AL, Fargion S, Romano R, Conte D, Piperno A, D'Alba R, et al. Portal hypertension and iron depletion in patients with genetic hemochromatosis. Hepatology. 1995;22(4 Pt 1):1127-31. Not a screening population. [pmid: 7557861].
Gleeson F, Ryan E, Barrett S, Crowe J. Clinical expression of haemochromatosis in Irish C282Y homozygotes identified through family screening. European Journal of Gastroenterology & Hepatology. 2004;16(9):859-63. Includes data from patients < 18 yrs. [pmid: 15316409].
Hallberg L, Bjorn-Rasmussen E, Jungner I. Prevalence of hereditary haemochromatosis in two Swedish urban areas. Journal of Internal Medicine. 1989;225(4):249-255. Does not include C282Y genotyping in screening sequence. [pmid: 2723582].
Halliday JW, Russo AM, Cowlishaw JL, Powell LW. Serum-ferritin in diagnosis of haemochromatosis. A study of 43 families. Lancet. 1977;2(8039):621-4. Does not report relevant outcomes. [pmid: 71445].
Hamilton EB, Bomford AB, Laws JW, Williams R. The natural history of arthritis in idiopathic haemochromatosis: progression of the clinical and radiological features over ten years. Quarterly Journal of Medicine. 1981;50(199):321-9. Not a screening population. [pmid: 7330169].
Jackson HA, Carter K, Darke C, Guttridge MG, Ravine D, Hutton RD, et al. HFE mutations, iron deficiency and overload in 10,500 blood donors. British Journal of Haematology. 2001;114(2):474-84. Study disease definition does not meet our definition of asymptomatic primary iron overload or clinical disease. [pmid: 11529872].
Jiang R, Manson JE, Meigs JB, Ma J, Rifai N, Hu FB. Body iron stores in relation to risk of type 2 diabetes in apparently healthy women. JAMA. 2004;291(6):711-7. Study design. [pmid: 14871914].
Jonsson JJ, Johannesson GM, Sigfusson N, Magnusson B, Thjodleifsson B, Magnusson S. Prevalence of iron deficiency and iron overload in the adult Icelandic population. Journal of Clinical Epidemiology. 1991;44(12):1289-1297. Does not include C282Y genotyping in screening sequence. [pmid: 1753260].
Jorquera F, Dominguez A, Diaz-Golpe V, Espinel J, Munoz F, Herrera A, et al. C282Y and H63D mutations of the haemochromatosis gene in patients with iron overload. Revista Espanola de Enfermedades Digestivas. 2001;93(5):293-302. Not a screening population. [pmid: 11488107].
Karlsson M, Ikkala E, Reunanen A, Takkunen H, Vuori E, Makinen J. Prevalence of hemochromatosis in Finland. Acta MedIca Scandinavica. 1988;224(4):385-390. Does not include C282Y genotyping in screening sequence. [pmid: 3188989].
Koefoed P, Dalhoff K, Dissing J, Kramer I, Milman N, Pedersen P, et al. HFE mutations and hemochromatosis in Danish patients admitted for HFE genotyping. Scandinavian Journal of Clinical & Laboratory Investigation. 2002;62(7):527-35. Not a screening population. [pmid: 12512743].
Lalouel JM, Le Mignon L, Simon M, Fauchet R, Bourel M, Rao DC, et al. Genetic analysis of idiopathic hemochromatosis using both qualitative (disease status) and quantitative (serum iron) information. American Journal of Human Genetics. 1985;37(4):700-18. Does not report relevant outcomes. [pmid: 9556659].
Leggett BA, Halliday JW, Brown NN, Bryant S, Powell LW. Prevalence of haemochromatosis amongst asymptomatic Australians. British Journal of Haematology. 1990;74(4):525-530. Does not include C282Y genotyping in screening sequence. [pmid: 2346731].
Lin E, Adams PC. Biochemical liver profile in hemochromatosis. A survey of 100 patients. Journal of Clinical Gastroenterology. 1991;13(3):316-20. Not a screening population. [pmid: 2066547].
Lindmark B, Eriksson S. Regional differences in the idiopathic hemochromatosis gene frequency in Sweden. Acta Medica Scandinavica. 1985;218(3):299-304. Does not include C282Y genotyping in screening sequence. [pmid: 4072776].
Livesey KJ, Wimhurst VL, Carter K, Worwood M, Cadet E, Rochette J, et al. The 16189 variant of mitochondrial DNA occurs more frequently in C282Y homozygotes with haemochromatosis than those without iron loading. Journal of Medical Genetics. 2004;41(1):6-10. Not a screening population. [pmid: 14729817].
Mainous AG III, Gill JM, Pearson WS. Should we screen for hemochromatosis? An examination of evidence of downstream effects on morbidity and mortality. Archives of Internal Medicine 162(15):1769–74, 2002;-26. Does not report relevant outcomes
Mainous AG III, King DE, Pearson WS, Garr DR. Is an elevated serum transferrin saturation associated with the development of diabetes?. J Fam Pract. 2002;51(11):933-936. Does not include C282Y genotyping in screening sequence. [pmid: 12485546].
Mainous AG III, Wells B, Carek PJ, Gill JM, Geesey ME. The mortality risk of elevated serum transferrin saturation and consumption of dietary iron. Annals of Family Medicine. Apr. 2004;2(2):139-44. Does not include C282Y genotyping in screening sequence. [pmid: 15083854].
Mainous AG III, Gill JM, Carek PJ. Elevated serum transferrin saturation and mortality. Ann Fam Med. 2004;2(2):133-138. Does not include C282Y genotyping in screening sequence. [pmid: 15083853].
Mainous AG III, Gill JM, Everet CJ. Transferrin saturation, dietary iron intake, and risk of cancer. Annals of Family Medicine. Apr. 2005;3(2):131-7. Does not report relevant outcomes. [pmid: 15798039].
Mathews JL, Williams HJ. Arthritis in hereditary hemochromatosis. Arthritis & Rheumatism. 1987;30(10):1137-41. Study design. [pmid: 3675659].
McCune CA, Al Jader LN, May A, Hayes SL, Jackson HA, Worwood M. Hereditary haemochromatosis: only 1% of adult HFEC282Y homozygotes in South Wales have a clinical diagnosis of iron overload. Human Genetics. 2002;111(6):538-43. Not a screening population. [pmid: 12436244].
McCune CA, Ravine D, Worwood M, Jackson HA, Evans HM, Hutton D. Screening for hereditary haemochromatosis within families and beyond. Lancet. 2003;362(9399):1897-8. Not a screening population Quality. [pmid: 14667749].
Merryweather-Clarke AT, Worwood M, Parkinson L, Mattock C, Pointon JJ, Shearman JD, et al. The effect of HFE mutations on serum ferritin and transferrin saturation in the Jersey population. British Journal of Haematology. 1998;101(2):369-73. Does not report relevant outcomes. [pmid: 9609537].
Milman N, Pedersen P, Steig T, Byg KE, Graudal N, Fenger K. Clinically overt hereditary hemochromatosis in Denmark 1948-1985: epidemiology, factors of significance for long-term survival, and causes of death in 179 patients. Annals of Hematology. 2001;80(12):737-44. Quality. [pmid: 11797115].
Milman N. Iron status markers in hereditary haemochromatosis: distinction between individuals being homozygous and heterozygous for the haemochromatosis allele. European Journal of Haematology. 1991;47(4):292-8. Does not report relevant outcomes. [pmid: 1954989].
Moirand R, Jouanolle AM, Brissot P, Le Gall JY, David V, Deugnier Y. Phenotypic expression of HFE mutations: a French study of 1110 unrelated iron-overloaded patients and relatives. Gastroenterology. 1999;116(2):372-7. Does not report relevant outcomes. [pmid: 9922318].
Moodie SJ, Ang L, Stenner JM, Finlayson C, Khotari A, Levin GE, et al. Testing for haemochromatosis in a liver clinic population: relationship between ethnic origin, HFE gene mutations, liver histology and serum iron markers. European Journal of Gastroenterology & Hepatology. 2002;14(3):223-9. Not a screening population. [pmid: 11953685].
Morrison ED, Brandhagen DJ, Phatak PD, Barton JC, Krawitt EL, El Serag HB, et al. Serum ferritin level predicts advanced hepatic fibrosis among U.S. patients with phenotypic hemochromatosis. Annals of Internal Medicine. 2003;138(8):627-33. Not a screening population. [pmid: 12693884].
Mura C, Nousbaum JB, Verger P, Moalic MT, Raguenes O, Mercier AY, et al. Phenotype-genotype correlation in haemochromatosis subjects. Human Genetics. 1997;101(3):271-6. Not a screening population. [pmid: 9439654].
Nash S, Marconi S, Sikorska K, Naeem R, Nash G. Role of liver biopsy in the diagnosis of hepatic iron overload in the era of genetic testing. American Journal of Clinical Pathology. 2002;118(1):73-81. Not a screening population. [pmid: 12109859].
Nelson RL, Persky V, Davis F, Becker E. Risk of disease in siblings of patients with hereditary hemochromatosis. Digestion. 2001;64(2):120-4. Quality. [pmid: 11684826].
Niederau C, Niederau CM, Lange S, Littauer A, Abdel-Jalil N, Maurer M, Haussinger D, Strohmeyer G. Screening for hemochromatosis and iron deficiency in employees and primary care patients in Western Germany. Annals of Internal Medicine. 1998;128(5):337-345. Does not include C282Y genotyping in screening sequence. [pmid: 9490593].
Olsson KS, Eriksson K, Ritter B, Heedman PA. Screening for iron overload using transferrin saturation. Acta Medica Scandinavica. 1984;215(2):105-112. Does not include C282Y genotyping in screening sequence. [pmid: 6702489].
Olsson KS, Ritter B, Lundin PM. Liver affection in iron overload studied with serum ferritin and serum aminotransferases. Acta Medica Scandinavica. 1985;217(1):79-84. Not a screening population. [pmid: 3976436].
Olynyk JK, Luxon BA, Britton RS, Bacon BR. Hepatic iron concentration in hereditary hemochromatosis does not saturate or accurately predict phlebotomy requirements. American Journal of Gastroenterology. 1998;93(3):346-50. Does not report relevant outcomes. [pmid: 9517637].
Panajotopoulos N, Piperno A, Conte D, Mandelli C, Cesana M, Mercuriali F, et al. HLA typing in 67 Italian patients with idiopathic hemochromatosis and their relatives. Tissue Antigens. 1989;33(4):431-6. Study design. [pmid: 2734773].
Phatak PD, Sham RL, Raubertas RF, Dunnigan K, O'Leary MT, Braggins C, Cappuccio JD. Prevalence of hereditary hemochromatosis in 16031 primary care patients. Annals of Internal Medicine. 1998;129(11):954-961. Does not include C282Y genotyping in screening sequence. [pmid: 9867748].
Piperno A, Vergani A, Salvioni A, Trombini P, Vigano M, Riva A, et al. Effects of venesections and restricted diet in patients with the insulin-resistance hepatic iron overload syndrome. Liver International. 2004;24(5):471-6. Not a screening population. [pmid: 15482345].
Porto G, Vicente C, Fraga J, da Silva BM, de Sousa M. Importance of establishing appropriate local reference values for the screening of hemochromatosis: a study of three different control populations and 136 hemochromatosis family members. Hemochromatosis Clinical and Research Group. Journal of Laboratory & Clinical Medicine. 1992;119(3):295-305. Includes data from patients < 18 yrs. [pmid: 1541878].
Porto G, Vicente C, Teixeira MA, Martins O, Cabeda JM, Lacerda R, Goncalves C, Fraga J, Macedo G, Silva BM, Alves H, Justica B, de Sousa M. Relative impact of HLA phenotype and CD4–CD8 ratios on the clinical expression of hemochromatosis. Hepatology. 1997;25(2):397-402. Not a screening population. [pmid: 9021953].
Poullis A, Moodie SJ, Ang L, Finlayson CJ, Levin GE, Maxwell JD. Routine transferrin saturation measurement in liver clinic patients increases detection of hereditary haemochromatosis. Annals of Clinical Biochemistry. 2003;40(Pt 5):521-7. Not a screening population. [pmid: 14503989].
Powell LW, Summers KM, Board PG, Axelsen E, Webb S, Halliday JW. Expression of hemochromatosis in homozygous subjects. Implications for early diagnosis and prevention. Gastroenterology. 1990;98(6):1625-32. Includes data from patients < 18 yrs. [pmid: 2338199].
Poynard T, Mathurin P, Lai CL, Guyader D, Poupon R, Tainturier MH, et al. A comparison of fibrosis progression in chronic liver diseases. Journal of Hepatology. 2003;38(3):257-65. Not a screening population. [pmid: 12586290].
Press RD, Flora K, Gross C, Rabkin JM, Corless CL. Hepatic iron overload: direct HFE (HLA-H) mutation analysis vs quantitative iron assays for the diagnosis of hereditary hemochromatosis. American Journal of Clinical Pathology. 1998;109(5):577-84. Not a screening population. [pmid: 9576576].
Rhodes DA, Raha-Chowdhury R, Cox TM, Trowsdale J. Homozygosity for the predominant Cys282Tyr mutation and absence of disease expression in hereditary haemochromatosis. Journal of Medical Genetics. 1997;34(9):761-4. Does not report relevant outcomes. [pmid: 9321765].
Roberts AG, Whatley SD, Morgan RR, Worwood M, Elder GH. Increased frequency of the haemochromatosis Cys282Tyr mutation in sporadic porphyria cutanea tarda. Lancet. 1997;349(9048):321-3. Does not report relevant outcomes. [pmid: 9024376].
Rossi E, Henderson S, Chin CY, Olynyk J, Beilby JP, Reed WD, et al. Genotyping as a diagnostic aid in genetic haemochromatosis. Journal of Gastroenterology & Hepatology. 1999;14(5):427-30. Not a screening population. [pmid: 10355506].
Rowe JW, Wands JR, Mezey E, Waterbury LA, Wright JR, Tobin J, Andres R. Familial hemochromatosis: characteristics of the precirrhotic stage in a large kindred. Medicine. 1977;56(3):197-211. Does not report relevant outcomes. [pmid: 870791].
Ryan E, Byrnes V, Coughlan B, Flanagan AM, Barrett S, O'Keane JC, Crowe J. Underdiagnosis of hereditary haemochromatosis: lack of presentation or penetration?. Gut. 2002;51(1):108-12. Includes data from patients < 18 yrs. [pmid: 12077102].
Salonen JT, Tuomainen TP, Kontula K. Role of C282Y mutation in haemochromatosis gene in development of type 2 diabetes in healthy men: prospective cohort study. BMJ. 2000;320(7251):1706-7. Does not report relevant outcomes. [pmid: 10864547].
Scotet V, Merour MC, Mercier AY, Chanu B, Le Faou T, Raguenes O, et al. Hereditary hemochromatosis: effect of excessive alcohol consumption on disease expression in patients homozygous for the C282Y mutation. American Journal of Epidemiology. 2003;158(2):129-34. Does not report relevant outcomes. [pmid: 12851225].
Sham RL, Ou CY, Cappuccio J, Braggins C, Dunnigan K, Phatak PD. Correlation between genotype and phenotype in hereditary hemochromatosis: analysis of 61 cases. Blood Cells Molecules & Diseases. 1997;23(2):314-20. Not a screening population.
Sham RL, Raubertas RF, Braggins C, Cappuccio J, Gallagher M, Phatak PD. Asymptomatic hemochromatosis subjects: genotypic and phenotypic profiles. Blood. 2000;96(12):3707-11. Not a screening population. [pmid: 11090050].
Smith BN, Kantrowitz W, Grace ND, Greenberg MS, Patton TJ, Ookubo R, Sorger K, Semeraro JG, Doyle JR, Coope AG, Kamat BR, Maregni LM, Rand WM. Prevalence of hereditary hemochromatosis in a Massachusetts corporation: is Celtic origin a risk factor?. Hepatology. 1997;25(6):1439-1446. Does not include C282Y genotyping in screening sequence. [pmid: 9185765].
Waalen J, Nordestgaard BG, Beutler E. The penetrance of hereditary hemochromatosis. Bailliere's Best Practice in Clinical Haematology. 2005;18(2):203-20. Review article.
Wands JR, Rowe JA, Mezey SE, Waterbury LA, Wright JR, Halliday JW, Isselbacher KJ, Powell LW. Normal serum ferritin concentrations in precirrhotic hemochromatosis. New England Journal of Medicine. 1976;294(6):302-5. Does not report relevant outcomes. [pmid: 1246269].
Wiggers P, Dalhoj J, Kiaer H, Ring-Larsen H, Petersen PH, Blaabjerg O, Horder M. Screening for haemochromatosis: prevalence among Danish blood donors. Journal of Internal Medicine. 1991;230(3):265-270. Does not include C282Y genotyping in screening sequence. [pmid: 1895049].
Willis G, Jennings BA, Goodman E, Fellows IW, Wimperis JZ. A high prevalence of HLA-H 845A mutations in hemochromatosis patients and the normal population in eastern England. Blood Cells Molecules & Diseases. 1997;23(2):288-91. Does not report relevant outcomes.
Willis G, Wimperis JZ, Lonsdale R, Fellows IW, Watson MA, Skipper LM, et al. Incidence of liver disease in people with HFE mutations. Gut. 2000;46(3):401-4. Does not report relevant outcomes. [pmid: 10673304].
Willis G, Wimperis JZ, Smith K, Fellows IW, Jennings BA. HFE mutations in the elderly. Blood Cells Molecules & Diseases. 2003;31(2):240-6. Oct. Study disease definition does not meet our definition of asymptomatic primary iron overload or clinical disease.
Wojcik JP, Speechley MR, Kertesz AE, Chakrabarti S, Adams PC. Natural history of C282Y homozygotes for hemochromatosis. Canadian Journal of Gastroenterology. 2002;16(5):297-302. Not a screening population Includes data from patients < 18 yrs. [pmid: 12045778].
Yamashita C, Adams PC. Natural history of the C282Y homozygote for the hemochromatosis gene (HFE) with a normal serum ferritin level. Clin Gastroenterol Hepatol. 2003;1(5):388-391. Not a screening population. [pmid: 15017658].

## Table 3. Studies pending assessment for key question 1

### Study Reference

Powell L, Dixon J, Ramm G, et al. The penetrance of HFE-associated hemochromatosis as assessed by liver biopsy in subjects identified by health checks, family screening or population screening. Hepatology. 2004;40:574A. Abstract from a meeting. No article published yet. [pmid: 15349895].
Falize L, Guillygomarch A. Perrin M, Laine F, Guyader D, Brissot P, Turlin B, Deugnier Y. Reversibility of hepatic fibrosis in treated genetic haemochromatosis a study of 28 cases. Bioiron Proceedings (May 2005) P234. Abstract from a meeting. No article published yet.