# Appendix B USPSTF Hierarchy of research design and quality rating criteria. ^50^

## Hierarchy of Research Design

- I Properly conducted randomized controlled trial (RCT)
- II-1: Well-designed controlled trial without randomization
- II-2: Well-designed cohort or case-control analytic study
- II-3: Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
- III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees

## Design-Specific Criteria

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance are especially important for systematic reviews

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

### Randomized Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
  - -for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  - -for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts

- Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of the interventions
- All important outcomes considered

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate result in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test