# Appendix A

Figure 1. Search results and article flow by key question

Figure 2. Abstract and article review process for hemochromatosis

## Search strategies

Databases: Medline, DARE, Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials

Dates searched: 1966–February 2005

### Key Question 1

1 HEMOCHROMATOSIS/
2 hemochromatosis.ti,ab.
3 haemochromatosis.ti,ab.
4 Iron Overload/
5 iron overload.ti,ab.
6 c282y.ti,ab.
7 1 or 2 or 3 or 4 or 5 or 6
8 cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/
9 follow-up stud$.ti,ab.
10 cohort stud$.ti,ab.
11 longitudinal$.ti,ab.
12 prospective$.ti,ab.
13 INCIDENCE/
14 incidence.ti,ab.
15 predict$.ti,ab,hw.
16 natural history.ti,ab.
17 penetrance/
18 penetran$.ti,ab.
19 clinical expression$.ti,ab.
20 clinical presentation$.ti,ab.
21 clinical consequence$.ti,ab.
22 clinical feature$.ti,ab.
23 clinical manifestation$.ti,ab.
24 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23
25 7 and 24
26 limit 25 to (humans and english language)
27 limit 26 to “all child (0 to 18 years)”
28 limit 27 to “all adult (19 plus years)”
29 27 not 28
30 26 not 29
31 (editorial or letter or news).pt.
32 30 not 31

### Key Question 2

1 HEMOCHROMATOSIS/
2 hemochromatosis.ti,ab.)
3 haemochromatosis.ti,ab.
4 Iron Overload/
5 iron overload.ti,ab.
6 1 or 2 or 3 or 4 or 5
7 BLOODLETTING/
8 blood lett$.ti,ab.)
9 PHLEBOTOMY/
10 phlebotom$.ti,ab.
11 venesect$.ti,ab.
12 7 or 8 or 9 or 10 or 11
13 6 and 12
14 Hemochromatosis/th [Therapy]
15 Iron Overload/th [Therapy]
16 13 or 14 or 15
17 limit 16 to (humans and english language)
18 limit 17 to “all child (0 to 18 years)”
19 limit 18 to “all adult (19 plus years)”
20 18 not 19
21 17 not 20
22 (editorial or letter or news).pt.
23 21 not 22

### Key Question 3

1 HEMOCHROMATOSIS/
2 hemochromatosis.ti,ab.
3 haemochromatosis.ti,ab.
4 1 or 2 or 3
5 family/ or nuclear family/ or parents/ or fathers/ or mothers/ or siblings/
6 (family or families).ti,ab.
7 (relative or relatives).ti,ab.
8 sibling$.ti,ab.
9 (mother$ or father$).ti,ab.
10 parent$.ti,ab.
11 5 or 6 or 7 or 8 or 9 or 10
12 screen$.ti,ab,hw.
13 diagnos$.ti,ab,hw.
14 di.fs.
15 12 or 13 or 14
16 4 and 11 and 15
17 target$.ti,ab.
18 4 and 15 and 17
19 Risk Factors/
20 risk factor$.ti,ab.
21 increased risk$.ti,ab.
22 high risk.ti,ab.
23 prognostic factor$.ti,ab.
24 19 or 20 or 21 or 22 or 23
25 4 and 24
26 cascad$.ti,ab.
27 4 and 26
28 Liver Function Tests/
29 liver function.ti,ab.
30 (abnormal$ adj3 liver).ti,ab.
31 (increased adj3 liver).ti,ab.
32 (elevate$ adj3 liver).ti,ab.
33 28 or 29 or 30 or 31 or 32
34 4 and 33
35 16 or 18 or 25 or 27 or 34
36 limit 35 to english language
37 limit 36 to humans
38 limit 37 to “all child (0 to 18 years)”
39 limit 38 to “all adult (19 plus years)”
40 38 not 39
41 37 not 40
42 (editorial or letter or news).pt.
43 41 not 42

### Background

1 hemochromatosis)
2 hemochromatosis.ti,ab.
3 haemochromatosis.ti,ab.
4 1 or 2 or 3
5 PREVALENCE/
6 prevalen$.ti,ab.
7 5 or 6
8 4 and 7
9 HEMOCHROMATOSIS/ep [Epidemiology]
10 mo.fs.
11 “Cause of Death”/
12 Survival Rate/
13 Life Expectancy/
14 mortality.ti,ab.
15 10 or 11 or 12 or 13 or 14
16 4 and 15
17 8 or 9 or 16
18 limit 17 to english language
19 limit 18 to humans
20 limit 19 to “all child (0 to 18 years)”
21 limit 20 to “all adult (19 plus years)”
22 20 not 21
23 19 not 22
24 (letter or news or editorial).pt.
25 23 not 24