# References

1 U.S.Preventive Services Task Force. Guide to Clinical Preventive Services: An assessment of the effectiveness of 169 interventions. Baltimore: Williams & Wilkins, 1989.
2 U.S.Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Baltimore: Williams & Wilkins, 1996.
3 Pietrangelo A. Hereditary hemochromatosis—a new look at an old disease. New England Journal of Medicine. 2004;350(23):2383-2397. [pmid: 15175440].
4 Adams P, Brissot P, Powell LW. EASL International Consensus Conference on Haemochromatosis. Journal of Hepatology. 2000;33(3):485-504. [pmid: 11020008].
5 Edwards CQ, Kushner JP. Screening for hemochromatosis. New England Journal of Medicine. 1993;328(22):1616-1620. [pmid: 8110209].
6 Powell LW, Isselbacher KJ. Hemochromatosis. Harrison's Principles of Internal Medicine. New York: McGraw Hill, 2001: 2257–2261.
7 Dubois S, Kowdley KV. Targeted screening for hereditary haemochromatosis in high-risk groups. Alimentary Pharmacology and Therapeutics. 2004;20(1):1-14. [pmid: 15225165].
8 Feder JN, Gnirke A, Thomas W, Tsuchihashi Z, Ruddy DA, Basava A, et al. A novel MHC class I-like gene is mutated in patients with hereditary haemochromatosis. Nature Genetics. 1996;13(4):399-408. [pmid: 8696333].
9 Hanson EH, Imperatore G, Burke W. HFE gene and hereditary hemochromatosis: a HuGE review. Human Genome Epidemiology. American Journal of Epidemiology. 2001;154(3):193-206. [pmid: 11479183].
10 Edwards CQ, Ajioka RS, Kushner JP. Hemochromatosis: A genetic definition. In: Barton JC, Edwards CQ, editors. Hemochromatosis: Genetics, Pathophysiology, Diagnosis and Treatment. Cambridge, UK: Cambridge University Press, 2000: 8–11.
11 Adams PC, Reboussin DM, Barton JC, McLaren CE, Eckfeldt JH, McLaren GD, et al. Hemochromatosis and iron-overload screening in a racially diverse population. New England Journal of Medicine. 2005;352(17):1769-1778. [pmid: 15858186].
12 Yang Q, McDonnell SM, Khoury MJ, Cono J, Parrish RG. Hemochromatosis-associated mortality in the United States from 1979 to 1992: an analysis of Multiple-Cause Mortality Data. Annals of Internal Medicine. 1998;129(11):946-953. [pmid: 9867747].
13 Adams PC. Hemochromatosis. Clinics in Liver Disease. 2004;8(4):735-753. [pmid: 15464653].
14 Piperno A. Expression of iron overload in hemochromatosis. In: Barton JC, Edwards CQ, editors. Hemochromatosis: Genetics, pathophysiology, diagnosis and treatment. Cambridge, UK: Cambridge University Press, 2000: 177–183.
15 Baynes RD. Interactions of alcohol, iron and hemochromatosis. In: Barton JC, Edwards CQ, editors. Hemochromatosis: Genetics, pathophysiology, diagnosis and treatment. Cambridge, UK: Cambridge University Press, 2000: 468–474.
16 Njajou OT, Alizadeh BZ, van Duijn CM. Is genetic screening for hemochromatosis worthwhile?. European Journal of Epidemiology. 2004;19(2):101-108. [pmid: 15074564].
17 Brissot P. Clinical spectrum of hepatic disease in hemochromatosis. In: Barton JC, Edwards CQ, editors. Hemochromatosis: Genetics, pathophysiology, diagnosis, and treatment. Cambridge, UK: Cambridge University Press, 2000: 250–257.
18 Sham RL, Raubertas RF, Braggins C, Cappuccio J, Gallagher M, Phatak PD. Asymptomatic hemochromatosis subjects: genotypic and phenotypic profiles. Blood. 2000;96(12):3707-3711. [pmid: 11090050].
19 CDC. http://www.cdc.gov/hemochromatosis/training/diagnostic_testing/testing_protocol.htm (Accesssed on 9/27/2005).
20 Adams PC. Is there a threshold of hepatic iron concentration that leads to cirrhosis in C282Y hemochromatosis?. American Journal of Gastroenterology. 2001;96(2):567-569. [pmid: 11232708].
21 Baldus WP, Batts KP, Brandhagen DJ. Liver biopsy in hemochromatosis. In: Barton JC, Edwards CQ, editors. Hemochromatosis: Genetics, pathophysiology, diagnosis and treatment. Cambridge, UK: Cambridge University Press, 2000: 187–199.
22 Niederau C, Fischer R, Sonnenberg A, Stremmel W, Trampisch HJ, Strohmeyer G. Survival and causes of death in cirrhotic and in noncirrhotic patients with primary hemochromatosis. New England Journal of Medicine. 1985;313(20):1256-1262. [pmid: 4058506].
23 Strohmeyer G, Niederau C, Stremmel W. Survival and causes of death in hemochromatosis. Observations in 163 patients. Annals of the NewYork Academy of Sciences. 1988;526:245-257.
24 Wojcik JP, Speechley MR, Kertesz AE, Chakrabarti S, Adams PC. Natural history of C282Y homozygotes for hemochromatosis. Canadian Journal of Gastroenterology. 2002;16(5):297-302. [pmid: 12045778].
25 Adams PC, Speechley M, Kertesz AE. Long-term survival analysis in hereditary hemochromatosis. Gastroenterology. 1991;101(2):368-372. [pmid: 2065912].
26 Niederau C, Fischer R, Purschel A, Stremmel W, Haussinger D, Strohmeyer G. Long-term survival in patients with hereditary hemochromatosis. Gastroenterology. 1996;110(4):1107-1119. [pmid: 8613000].
27 Eijkelkamp EJ, Yapp TR, Powell LW. HFE-associated hereditary hemochromatosis. Canadian Journal of Gastroenterology. 2000;14(2):121-125. [pmid: 10694284].
28 Cadet E, Capron D, Gallet M, Omanga-Leke ML, Boutignon H, Julier C, et al. Reverse cascade screening of newborns for hereditary haemochromatosis: a model for other late onset diseases?. Journal of Medical Genetics. 2005;42(5):390-395. [pmid: 15863667].
29 Brown AS, Gwinn M, Cogswell ME, Khoury MJ. Hemochromatosis-associated morbidity in the United States: an analysis of the National Hospital Discharge Survey, 1979-1997. Genetics in Med. 2001;3(2):109-111. [pmid: 11280947].
30 Ajioka RS, Kushner JP. Hereditary hemochromatosis. Seminars in Hematology. 2002;39(4):235-241. [pmid: 12382198].
31 McDonnell SM, Witte DL, Cogswell ME, McIntyre R. Strategies to increase detection of hemochromatosis. Annals of Internal Medicine. 1998;129(11):987-992. [pmid: 9867752].
32 Asberg A, Hveem K, Thorstensen K, Ellekjter E, Kannelonning K, Fjosne U, et al. Screening for hemochromatosis: high prevalence and low morbidity in an unselected population of 65,238 persons. Scandinavian Journal of Gastroenterology. 2001;36(10):1108-1115. [pmid: 11589387].
33 Beutler E, Felitti VJ, Koziol JA, Ho NJ, Gelbart T. Penetrance of 845G—> A (C282Y) HFE hereditary haemochromatosis mutation in the USA. Lancet. 2002;359(9302):211-218. [pmid: 11812557].
34 Beutler E. Natural history of hemochromatosis. Mayo Clinic Proceedings. 2004;79(3):305-306. [pmid: 15008601].
35 Poullis A, Moodie SJ, Maxwell JD. Clinical haemochromatosis in HFE mutation carriers. The Lancet. 2002;360(9330):411.
36 Cox T, Rochette J, Camaschella C, Walker A, Robson K. Clinical haemochromatosis in HFE mutation carriers. The Lancet. 2002;360(9330):412.
37 Allen KJ, Warner B, Delatycki MB. Clinical haemochromatosis in HFE mutation carriers. The Lancet. 2002;360(9330):412-413.
38 Beutler E, Felitti V, Koziol JA, Gelbart T. Clinical haemochromatosis in HFE mutation carriers. The Lancet. 2002;360(9330):413.
39 Ajioka RS, Kushner JP. Controversy in hematology: Rebuttal to Beutler. Blood. 2003;101(9):3358.
40 Beutler E. Controversy in hematology: Rebuttal to Ajioka and Kushner. Blood. 2003;101(9):3354-3357.
41 Bradley LA, Haddow JE, Palomaki GE. Population screening for haemochromatosis: a unifying analysis of published intervention trials. Journal of Medical Screening. 1996;3(4):178-187. [pmid: 9041481].
42 Cogswell ME, McDonnell SM, Khoury MJ, Franks AL, Burke W, Brittenham G. Iron overload, public health, and genetics: evaluating the evidence for hemochromatosis screening. Annals of Internal Medicine. 1998;129(11):971-979. [pmid: 9867750].
43 McDonnell SM, Parrish RG. Hereditary hemochromatosis and its elusive natural history. Archives of Internal Medicine. 2003;163(20):2421-2423. [pmid: 14609775].
44 Cogswell ME, Burke W, McDonnell SM, Franks AL. Screening for hemochromatosis. A public health perspective. American Journal of Preventive Medicine. 1999;16(2):134-140. [pmid: 10343890].
45 Phatak PD, Sham RL, Raubertas RF, Dunnigan K, O'Leary MT, Braggins C, et al. Prevalence of hereditary hemochromatosis in 16031 primary care patients. Annals of Internal Medicine. 1998;129(11):954-961. [pmid: 9867748].
46 Niederau C, Niederau CM, Lange S, Littauer A, Abdel-Jalil N, Maurer M, et al. Screening for hemochromatosis and iron deficiency in employees and primary care patients in Western Germany. Annals of Internal Medicine. 1998;128(5):337-345. [pmid: 9490593].
47 Witte DL, Crosby WH, Edwards CQ, Fairbanks VF, Mitros FA. Practice guideline development task force of the College of American Pathologists. Hereditary hemochromatosis. Clinica Chimica Acta. 1996;245(2):139-200.
48 Brittenham GM, Franks AL, Rickles FR. Research priorities in hereditary hemochromatosis. Annals of Internal Medicine. 1998;129(11):993-996. [pmid: 9867753].
49 Waalen J, Nordestgaard BG, Beutler E. The penetrance of hereditary hemochromatosis. Bailliere's Best Practices in Clinical Haematology. 2005;18(2):203-220.
50 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. 2001;20(3 Suppl):21-35. [pmid: 11306229].
51 Cochrane Non-Randomised Studies Methods Group 2005, available at http://www.cochrane.dk/nrsmg/ (Accessed on 4/18/2005).
52 Olynyk JK, Hagan SE, Cullen DJ, Beilby J, Whittall DE. Evolution of untreated hereditary hemochromatosis in the Busselton population: a 17-year study. Mayo Clinic Proceedings. 2004;79(3):309-313. [pmid: 15008603].
53 Andersen RV, Tybjaerg-Hansen A, Appleyard M, Birgens H, Nordestgaard BG. Hemochromatosis mutations in the general population: iron overload progression rate. Blood. 2004;103(8):2914-2919. [pmid: 15070663].
54 Beutler E, Felitti V, Gelbart T, Ho N. The effect of HFE genotypes on measurements of iron overload in patients attending a health appraisal clinic. Annals of Internal Medicine. 2000;133(5):329-337. [pmid: 10979877].
55 Beutler E, Felitti V, Ho NJ, Gelbart T. Relationship of body iron stores to levels of serum ferritin, serum iron, unsaturated iron binding capacity and transferrin saturation in patients with iron storage disease. Acta Haematology. 2002;107(3):145-149.
56 Deugnier Y, Jouanolle AM, Chaperon J, Moirand R, Pithois C, Meyer JF, et al. Gender-specific phenotypic expression and screening strategies in C282Y-linked haemochromatosis: a study of 9396 French people. British Journal of Haematology. 2002;118(4):1170-1180. [pmid: 12199803].
57 Phatak PD, Ryan DH, Cappuccio J, Oakes D, Braggins C, Provenzano K, et al. Prevalence and penetrance of HFE mutations in 4865 unselected primary care patients. Blood Cells Molecules and Diseases. 2002;29(1):41-47.
58 Waalen J, Felitti V, Gelbart T, Ho NJ, Beutler E. Penetrance of hemochromatosis. Blood Cells Molecules and Diseases. 2002;29(3):418-432.
59 Adams PC, Kertesz AE, McLaren CE, Barr R, Bamford A, Chakrabarti S. Population screening for hemochromatosis: a comparison of unbound iron-binding capacity, transferrin saturation, and C282Y genotyping in 5,211 voluntary blood donors. Hepatology. 2000;31(5):1160-1164. [pmid: 10796893].
60 Sanchez M, Villa M, Ingelmo M, Sanz C, Bruguera M, Ascaso C, et al. Population screening for hemochromatosis: a study in 5370 Spanish blood donors. Journal of Hepatology. 2003;38(6):745-750. [pmid: 12763366].
61 Chambers V, Sutherland L, Palmer K, Dalton A, Rigby AS, Sokol R, et al. Haemochromatosis-associated HFE genotypes in English blood donors: age-related frequency and biochemical expression. Journal of Hepatology. 2003;39(6):925-931. [pmid: 14642607].
62 Olynyk JK, Cullen DJ, Aquilia S, Rossi E, Summerville L, Powell LW. A population-based study of the clinical expression of the hemochromatosis gene. New England Journal of Medicine. 1999;341(10):718-24. [pmid: 10471457].
63 Burt MJ, George PM, Upton JD, Collett JA, Frampton CM, Chapman TM, et al. The significance of haemochromatosis gene mutations in the general population: implications for screening. Gut. 1998;43(6):830-836. [pmid: 9824612].
64 Distante S, Berg JP, Lande K, Haug E, Bell H. High prevalence of the hemochromatosis-associated Cys282Tyr HFE gene mutation in a healthy Norwegian population in the city of Oslo, and its phenotypic expression. Scandinavian Journal of Gastroenterology. 1999;34(5):529-534. [pmid: 10423072].
65 McDonnell SM, Hover A, Gloe D, Ou CY, Cogswell ME, Grummer-Strawn L. Population-based screening for hemochromatosis using phenotypic and DNA testing among employees of health maintenance organizations in Springfield, Missouri. American Journal of Medicine. 1999;107(1):30-37. [pmid: 10403350].
66 Delatycki MB, Allen KJ, Nisselle AE, Collins V, Metcalfe S, Du SD et al. Use of community genetic screening to prevent HFE-associated hereditary haemochromatosis. Lancet published online, www.thelancet.com, (Accessed on 4/26/2005).
67 Barton JC, Rothenberg BE, Bertoli LF, Acton RT. Diagnosis of hemochromatosis in family members of probands: a comparison of phenotyping and HFE genotyping. Genetics in Medicine. 1999;1(3):89-93. [pmid: 11336458].
68 Adams PC, Chakrabarti S. Genotypic/phenotypic correlations in genetic hemochromatosis: evolution of diagnostic criteria. Gastroenterology. 1998;114(2):319-323. [pmid: 9453492].
69 Bomford A, Williams R. Long term results of venesection therapy in idiopathic haemochromatosis. Quarterly Journal of Medicine. 1976;45(180):611-623. [pmid: 188063].
70 Williams R, Smith PM, Spicer EJ, Barry M, Sherlock S. Venesection therapy in idiopathic haemochromatosis. An analysis of 40 treated and 18 untreated patients. Quarterly Journal of Medicine. 1969;38(149):1-16. [pmid: 4303815].
71 McDonnell SM, Preston BL, Jewell SA, Barton JC, Edwards CQ, Adams PC, et al. A survey of 2,851 patients with hemochromatosis: symptoms and response to treatment. American Journal of Medicine. 1999;106(6):619-624. [pmid: 10378618].
72 McCune CA, Ravine D, Worwood M, Jackson HA, Evans HM, Hutton D. Screening for hereditary haemochromatosis within families and beyond. Lancet. 2003;362(9399):1897-1898. [pmid: 14667749].
73 Poullis A, Moodie SJ, Ang L, Finlayson CJ, Levin GE, Maxwell JD. Routine transferrin saturation measurement in liver clinic patients increases detection of hereditary haemochromatosis. Annals of Clinical Biochemistry. 2003;40(Pt 5):521-527. [pmid: 14503989].
74 Moodie SJ, Ang L, Stenner JM, Finlayson C, Khotari A, Levin GE, et al. Testing for haemochromatosis in a liver clinic population: relationship between ethnic origin, HFE gene mutations, liver histology and serum iron markers. European Journal of Gastroenterology and Hepatology. 2002;14(3):223-229. [pmid: 11953685].
75 Cadet E, Capron D, Perez AS, Crepin SN, Arlot S, Ducroix JP, et al. A targeted approach significantly increases the identification rate of patients with undiagnosed haemochromatosis. Journal of Internal Medicine. 2003;253(2):217-224. [pmid: 12542563].
76 Rosenqvist M, Hultcrantz R. Prevalence of a haemochromatosis among men with clinically significant bradyarrhythmias. European Heart Journal. 1989;10(5):473-478. [pmid: 2788086].
77 Swinkels DW, Aalbers N, Elving LD, Bleijenberg G, Swanink CM, van der Meer JW. Primary haemochromatosis: a missed cause of chronic fatigue syndrome?. Netherland Journal of Medicine. 2002;60(11):429-433.
78 Willis G, Scott DG, Jennings BA, Smith K, Bukhari M, Wimperis JZ. HFE mutations in an inflammatory arthritis population. Rheumatology (Oxford). 2002;41(2):176-179. [pmid: 11886966].
79 Waalen J, Felitti V, Gelbart T, Ho NJ, Beutler E. Prevalence of coronary heart disease associated with HFE mutations in adults attending a health appraisal center. American Journal of Medicine. 2002;113(6):472-479. [pmid: 12427496].
80 Imperatore G, Pinsky LE, Motulsky A, Reyes M, Bradley LA, Burke W. Hereditary hemochromatosis: perspectives of public health, medical genetics, and primary care. Genetics in Medicine. 2003;5(1):1-8. [pmid: 12544469].
81 Harrison H, Adams PC. Hemochromatosis. Common genes, uncommon illness? Canadian Family Physician 48:1326 –33, 2002; 48:1326–1333.
82 Wetterhall SF, Cogswell ME, Kowdley KV. Public health surveillance for hereditary hemochromatosis. Annals of Internal Medicine. 1998;129(11):980-986. [pmid: 9867751].