# Conclusions

Based on this focused evidence review, research regarding screening for HH remains very limited. Despite the availability of new studies in response to calls for improved research, ^18,^ ^48,^ ^82^ not enough is known yet to allow a confident projection of the impact or benefit from wide-spread genotypic screening for HH. Data are beginning to be reported for targeted high-risk population screening approaches (e.g., high-risk identification followed by phenotypic screening followed by genotypic screening).

Recent studies suggest that disease expression or penetrance is less than 100% in C282Y homozygotes identified through some method of screening. How much less than 100% and for whom remains uncertain. In the next year or two, the HEIRS followup should provide information on short-term disease expression based on clinical exams of C282Y homozygotes, those with elevated iron measures at the time of screening, regardless of genotype, and a sample of controls. However, only self-reported disease expression data is available on all 99,000 genotyped and phenotyped primary care patients and follow-up beyond 1 to 2 years is not planned. If funding is provided, this study could be a rich resource of prospective information on disease development as well as observational data on treatment response in contemporarily diagnosed patients with clear disease definition. Without other data, such as might come from the HEIRS study, the literature on treatment remains quite small, consisting of dated case series in less than 500 patients (few of whom have HH documented by genotype). Controlled treatment trials will probably never be undertaken for ethical reasons, so higher quality observational treatment data would be very useful.

The limited literature on genotyping family members of C282Y/C282Y probands suggests a higher proportion of homozygous family members are C282Y homozygotes and that these are more likely to have phenotypic expression, compared with those identified from other screening approaches. This literature is also of limited quantity due to the relatively recent availability of HFE testing (1996), but there is a large body of HLA-based literature on which family screening of probands has been established. Research needs in this area remain high. ^80^