# Discussion

## Natural History/Burden of Disease (Key Question 1)

We considered C282Y homozygotes identified through genotyping general population groups separately from those identified through genotyping family members of a known C282Y homozygote, to allow for differences in other factors affecting disease development (penetrance).

In the general population, two fair-to-good quality population-based cohort studies reported the risk of developing signs or symptoms of iron overload and hemochromatosis in 33 C282Y homozygote adults monitored for 17 to 25 years. Another 13 fair-to-good quality cross-sectional studies reported on the burden of disease at the time of identification for an additional 228 newly identified C282Y homozygote adults identified from the general population. Taken together these data suggest that 38 to 50% of C282Y homozygotes develop iron overload meeting our criteria and 10 to 25% develop definite disease. These data do not establish estimates of disease penetrance as they represent very small numbers of people (10 total C282Y homozygotes from longitudinal studies), and disease development could still occur in persons with longer-follow-up. Indeed, eight of 33 of those followed longitudinally were females age 50 or under at last follow-up, in whom disease may not have yet developed. And, it should be kept in mind that the clinical significance of iron overload is less clear than that of clinical hemochromatosis.

In family members of probands, there are no longitudinal studies reported of C282Y homozygotes identified through screening family members, but two cross-sectional studies suggest that the prevalence of C282Y homozygosity in family members is higher, as is the disease burden, compared with C282Y homozygotes identified through general population screening means. These data may not be very precise, however, due to potential selection biases and uncontrolled observations. Equally limited data suggest 49 to 86% of C282Y homozygotes from family screening will meet iron overload criteria and 8% will have cirrhosis. These data support the current clinical practice of genotyping and phenotyping family members of probands to identify and treat affected members. There are other ethical, legal, social, and psychological issues associated with family screening, however. ^80^

## Benefits of Early Treatment (Key Question 2)

Therapeutic phlebotomy studies examining survival and morbidity after treatment are limited to three case series reporting on a total of 447 patients diagnosed between 1937 and 1989. Two studies provide additional data on response to treatment. Disease severity at diagnosis and survival showed pronounced secular trends over this time period. More recently diagnosed patients are less-severely affected and show 10-year survival rates with treatment similar to those of age- and sex-matched controls. Available data are consistent with improvements after treatment in some but not all hemochromatosis-related morbidities; however, none of these data are controlled, and studies do not generally ensure minimally valid measures of treatment response. Treatment may result in reduced insulin doses in insulin-dependent diabetics and elevated liver enzymes reductions. Liver biopsies before and after treatment suggest arresting of disease progression in most individuals, and a possible reduction in the severity of hepatic fibrosis, particularly in less severely affected patients. Symptoms such as extreme fatigue, abdominal pain, and lethargy improve in the majority of patients while arthralgia and impotence do not. Harms were not reported in any studies.

## High-Risk Groups (Key Question 3)

Family members of individuals with HH are at higher risk of having hemochromatosis, and family screening has been established as a standard of care based on HLA-typing studies of family members of probands. ^80,^ ^81^ We found two U.S. studies using HFE-genotyping to determine risk in probands and family members that support this practice. A high proportion of tested biologic relatives (14 to 49%) are also C282Y homozygotes. The highest proportion (49%) is seen in family members of probands identified clinically (as opposed to screening), although these data have limitations as discussed above.

Some have suggested a targeted approach to screening by identifying persons with signs or symptoms consistent with undiagnosed, early-stage hemochromatosis. Seven cross-sectional studies examined the proportion of patients with a range of hemochromatosis-consistent diseases or symptoms taken from various settings that were C282Y homozygotes. Findings may not be conclusive as many comparisons were based on fewer than 300 patients, which may be insufficient given the population prevalence of C282Y homozygotes (3 to 5 per 1000 Caucasians). Primary care patients selected for signs or symptoms had the same prevalence of C282Y homozygosity as did healthy controls; patients from rheumatology clinics and with a history of coronary or other cardiac disease showed no greater prevalence of C282Y homozygosity. A higher proportion of C282Y homozygotes could be identified by genotyping liver clinic patients pre-screened to have TS above 45% (7.7% C282Y/C282Y) or by targeting diabetics hospitalized for poor control or complications (5.5%) or patients who were referred to specialists for chronic fatigue and arthralgias (5.7%). While biochemical screening with TS and SF further enriched this patient pool, calculated specificity remained low (56 to 67%).

## Overall Evidence

The quantity of evidence that met quality and relevance criteria for the focused key questions posed by this review was small, despite a very large published literature. After reviewing 1886 abstracts and 255 full-text articles, we located only 34 fair-to-good quality studies that were relevant to some aspect of our three key questions on burden of disease, benefits of early treatment, and high-risk groups. Reasons for study exclusions are listed in our excluded studies tables. Some articles often cited to support screening and treatment benefits in this field did not meet minimal quality criteria for our review, as was true of often-cited data within the studies we could include. All of the reviewed evidence, including treatment studies, was observational, much of it representing the experience of a small number of relatively selective individuals, and much of it without data to allow comparisons with an unaffected population. The published research was often difficult to interpret consistently and accurately given incompleteness and extreme variability in reporting standards.

In reviewing this field, others have included a larger range of study designs, such as modeling expected genotyping frequency in older populations, autopsy studies, and other circumstantial approaches. Our focused key questions did not allow this type of evidence into our review, but it is unlikely that their inclusion would be of great use to the USPSTF, given its evidence hierarchy and requirement of at least fair quality evidence for making its recommendations. ^50^

## Limitations

The research literature for this field is extensive, but it is primarily retrospective, observational, and descriptive as opposed to analytical. A great deal was published prior to the availability of HFE genotyping for HH.

The articles we included required significant interpretation for data abstraction and synthesis. For individual articles, we typically reviewed all tables for possibly relevant data and checked text calculations. We made every effort to report data only on adult populations relevant to screening, which required careful reading and data dissection in studies that combined cases from many sources. We excluded studies with serious discrepancies or where outcomes could not be related back to a sample or population source we were addressing. Many articles required further hand calculations to extract data in the most comparable form to allow cross-study comparisons, and inconsistencies between tables and text in many articles complicated this process. The number of calculations and interpretation from descriptive data raise a concern about data errors. We screened a significant amount of literature to try and locate quality, relevant research in a relatively short time period; although we may have missed some articles or reported data that contained some information relevant to these key questions, none was brought to our attention by peer reviewers. Overall, the difficulties in understanding and interpreting this literature posed challenges to meet our usual standards of comprehensiveness and consistency.

We primarily focused on HH as the condition of interest for this screening review, and within that, on the most common associated HFE genotype in the U.S. (C282Y homozygosity), which accounts for 85 to 90% of cases in Caucasians. We did not examine other hereditary causes or the impact of HFE heterozygosity that may account for 3 to 5% of HH patients. Due to the focused nature of this review, studies that might have indirectly informed the data reviewed for each key question were excluded.