# Results

## Key Question 1. Among those with a homozygous C282Y genotype, what is the risk of developing clinical hemochromatosis?

Out of 133 full-text studies examined for both of these questions, we excluded 115 studies for reasons specified by our inclusion/exclusion criteria (Appendix C Table 2.). We eliminated all studies that reported on morbidity in a mixed source population (persons identified from more than one of family, clinical, and healthy populations) using combined measures only, due to potential differences in disease expression between these groups. We eliminated studies that did not report actual morbidities associated with clinical hemochromatosis (or at least iron overload) among participants. Other primary reasons for study exclusions included reporting on samples that did not derive from any population—particularly one that could be subject to screening—and for reporting study data that could not fit within our hemochromatosis-related definitions. Two studies were identified but not published at the time of this report (Appendix C Table 3).

Summary of findings. The best evidence available came from longitudinal studies reporting the risk of developing disease in initially undiseased persons. Cross-sectional studies were more plentiful, but provide an estimate of disease expression only at the time of examination.

Although there are no longitudinal studies in inception cohorts, two fair-to-good quality retrospective cohort studies from Australia ^52^ and Denmark ^53^ report on disease expression (penetrance) of 33 C282Y homozygotes (22 women and 11 men) over 17 to 25 years of follow-up. Participants' average age at the end of observation was 47 to 63 years, however, eight females were 50 years or younger at final follow-up. This represents 8 of 33 (24%) of those observed who may not yet have reached an age to manifest clinical expression. Most (61 to 75%), but not all, of participants had elevated serum iron parameters by the end of observation. In the Australian study only, iron overload was objectively evaluated by liver biopsy in six of 10 participants. Iron overload was detected in five of 10 participants in the study. Considering both studies together, two of 33 developed diabetes and six of 33 had arthralgias. By clinical examination, none of the 23 Danish patients had liver disease, cardiomyopathy, or hypogonadism. Considering the two studies together, liver disease is clearly present in 3/33. Progression of iron accumulation did not appear inevitable, particularly as measured by SF, since a number of individual patients showed decreases or no change in SF levels over time, despite a lack of treatment or plausible explanation such as blood donation or loss.

In 13 cross-sectional studies, C282Y homozygotes were identified through three health clinics, ^33,^ ^54^ – ^58^ in blood donor settings, ^59^ – ^61^ through mass screening, ^62^ through voter rolls or employment screening, ^63^ – ^66^ or through family screening. ^67,^ ^68^ Disease expression at the time of identification was available for C282Y homozygotes identified through non-family-based genetic screening of 67,771 patients or from genotyping over 200 family members of probands. Seven cross-sectional studies provide adequate data to estimate the prevalence of iron overload and disease at the time of screening in the general population. ^33,^ ^56,^ ^62^ – ^66^ Among a total of 228 not previously identified C282Y homozygotes, 38% of those further evaluated met criteria for iron overload, 25% had liver fibrosis, and 6% had cirrhosis. These estimates could be too high (if the untested C282Y homozygotes are not as likely to be penetrant) or too low (if the other untested C282Y homozygotes are more likely to be penetrant) and should be viewed with caution as they are based on very small numbers. Limited data from genotyping family members of probands were consistent with a higher proportion of iron overload (49 to 86%) or cirrhosis (8%) in C282Y homozygotes identified through family screening than from general population screening.

Individual longitudinal studies. (Table 4) A good-quality retrospective cohort study examined biochemical and clinical study data gathered over the prior 17 years in 10 of 12 newly identified C282Y homozygotes (six females; four males) from genotyping the surviving Busselton, Australia cohort in 1998. ^52^ By the median age of 43, nine of 10 had TS above 45%, and five of 10 had SF levels above 300 μg/L. All subjects showed increased TS over time, while SF increased in four patients, stayed the same in four patients, and decreased in two patients. Decreases could not be explained by blood loss or donation. By the median age of 47 years, six of 10 patients had SF levels above 500 μg/L and they underwent liver biopsy. Five of six patients biopsied had hepatic iron concentrations above 90 micromoles/gram (moderate iron overload according to HEIRS standards). One of six patients had cirrhosis, and that person reported alcohol intake above six drinks per day. Two other patients had fibrosis and one of 10 had diabetes unrelated to HH. Comparative data were not provided for other genotypes. Selective mortality bias could have influenced these findings to represent the healthier homozygotes, although the C282Y/C282Y prevalence was 5.3 per 1000, and data were completed on 83% of the sample. However, how well these data represent life-long disease penetrance is in question. Two reports of the same data suggest different ages for participants at final follow-up. Based on a previous report of the same data, five females were 50 years or under at follow-up, while the other five C282Y homozygotes were males over 40 years or females over 50 years. ^62^

Table 4 Longitudinal studies of disease development in C282Y homozygotes

| | Screening | | Iron Overload | | Morbidity
Study Ref | Population | Criteria*/sequence | Results | Criteria* | Results | Definitiion | Results | Quality
Olynyk, 2004 ^52^ | Retrospective examination of 3011 randomly selected subjects (ages 20–79 y) from Busselton cohort genotyped in 1998. Available data: 1981, 1994, & 1998 | HFE genotype | 16/3011 C282YY, 4 previously diagnosed and undergoing TP. These 4 excluded. Serum available on 10/12. | >90 μm/g | 5/6 biopsied in 1998 | Fibrosis (6 biopsied) | 2/6 | Good
| | Elevated Iron Parameters TS > 45% | 1981: 3 of 9 Median age: 30 y 1994: 9 of 10 Median age: 43 y 1998: 10 of 10 | | | Cirrhosis | 1 of 6 (cirrhotic patient drank > 6 alcohol drinks/day)
| | SF > 300 | Median age: 47 y | | | DM | 1 subject at 19 yr thought unrelated to HC
| | | 1981: 5/10 | Possible Iron Overload | | Arthralgia | 4/10
| | | 1994: 5/10 4/5 were same | M: TS >50, SF > 300 | 4/4 (calculated)
| | | 1998: 6/10 | F: TS >45, SF >200 | 2/6 (calculated)
Andersen, 2004 ^53^ | Retrospective cohort from Copenhagen Heart study 1976-2001 n = 9,174 White: > 99%47% (9,174/19,698) of original Copenhagen study population | HFE Genotype C282Y:C282Y | 23/9174 | Possible Iron Overload Criteria: | | DM | 1/23 (4%) | Fair
| | TS > 50 in 2001 SF > 250 in 2001 SF> 200 in 2001 | 20 still alive M: 5/7, F: 13/16 M: 6/7 F: 10/16 | M: TS >50, SF >300, and CE F: TS >45, SF >200, and CE | 5/7 (calculated) 9/16 (calculated | Liver disease as defined by AST > 50 Alk phos >275 Coag < 70% Bili > 17 Clinical workups in 2001 for liver disease, hypogonadism, cardiomyopathy For arthralgias | 0/23 (0%)
| | [underlined: Iron measure progression: (1976-2001)] | | Liver biopsies not done | | Subclinical HC | 0/23
| | Transferrin Saturation Female Mean age: 25 y Mean age: 85 y Male Mean age: 35 y Mean age: 80 y | Mean: 50 Mean: 70 Mean: 70 Mean: 80 | | | | 2/23
| | Serum Ferritin Female Mean age: 25 y Mean age: 85 y Male Mean age: 35 y Mean age: 80 y | Mean: 120 Mean: 500 Mean: 800 Mean: 400 | | | | 1/23

* Criteria defined in Table 2.Selected C282YY-% positives in subset of C282Y homozygotes tested; All C282YY-% positives in all C282Y homozygotes.C282YY- C282Y/C282Y; NHANES-National Health and Nutrition Examination Survey ; TS-transferrin saturation; SF-serum ferritin; DM-diabetes mellitus; HR-; M-male; F-female; HIO-hepatic iron index; HIC-hepatic iron content; TP-therapeutic phlebotomy; Med-median; HC-hemochromatosis; AST-aspartate aminotransferase; Alk phos-alkaline phosphatase; Coag-coagulation tests; Bili-bilirubin.

A fair-quality retrospective and prospective cohort study, originally selected to represent the general population of Denmark, genotyped 9174 individuals at their third examination in 1991 to 1994 (65% of the original sample). ^53^ Twenty-three individuals were C282Y homozygotes (0.25%) and were matched according to age, sex, and alcohol consumption to two individuals with two other genotypes: wild type/wild type; compound heterozygote (C282Y/H63D). At the 2001 study examination, which included examination by a hemochromatosis specialist, 20 of 23 were still alive. In 2001 (or the last study examination for patients who had died), 9 of 16 C282Y homozygote females and 5 of 7 C282Y homozygote males met biochemical screening criteria for iron overload (TS > 45% and SF > 200 μg/L in females; TS > 50% and SF > 300 μg/L in males). At their last contact, female patients' mean age was 63.5 years, and 3 of 16 were 50 years old or younger, 7 male patients had a mean age of 61.8 years, and none were 40 years old or younger. C282Y homozygotes tended to have higher average TS and SF than other genotypes, with the exception of SF in males. Not all homozygotes, however, showed an increase in iron parameters over time and iron parameter levels showed more substantial individual variation over time than other genotypes. One of 23 C282Y homozygotes (male, age 45 years) was diagnosed with sub-clinical hemochromatosis. In 2001, no C282Y homozygotes had evidence of liver disease, based on symptoms and biochemical tests (no biopsies), and 1 patient had insulin-treated diabetes. Other hemochromatosis signs or symptoms (hypogonadism, cardiomyopathy, arthritis) were rare. Selective mortality bias may be a concern, as 35% of the original sample was not genotyped and the prevalence of C282Y homozygosity in those remaining to be tested was relatively low (0.25%). The authors state “the C282Y/C282Y genotype frequencies found in the remaining cohort did not differ from that predicted by the Harvey-Weinberg equilibrium.” Also, 3 of 23 patients died before genotyping (none from apparent hemochromatosis-related causes). However, the upper bound of morbidity can be calculated for disease penetrance. If all 3 patients among the 23 patients died from hemochromatosis, the proportion developing hemochromatosis-related disease would still be at about one-quarter (4/23). If the 35% of the cohort lost to follow-up had the usual population prevalence of C282Y homozygosity (5/1000), then about 25 C282Y homozygotes would have been lost to follow-up. If all of them fully developed clinical disease, then penetrance would be 60% (29/48) at the time of follow-up.

Individual cross-sectional studies. Morbidity findings in newly identified C282Y homozygotes from health clinics (n=50,434), the general population (3011), and voter roles and employee screening settings (14,326) are detailed in Appendix C Table 1. We kept three blood donor studies (n=16,842) separate and used them to estimate the lower bound of elevated iron parameters in C282Y homozygotes identified through general population genetic screening. Blood donors were not used to estimate iron overload or morbidities in C282Y homozygotes due to lack of data and because disease prevalence could be affected by donor policies (identifying and eliminating known C282Y homozygotes) and disease expression could be affected by the treatment effect of frequent blood donation. Two family screening studies reported iron parameters along with morbidity in 25 C282Y homozygotes identified from screening 150 family members ^67^ and of iron overload according to hepatic criteria in 51 C282Y homozygotes identified from screening an unspecified number of family members. ^68^

The similarity of findings for C282Y prevalence and phenotypic screening in health clinics, general population, voter roles, and employee screening studies allowed them to be considered together as “general population” (Table 5). The prevalence of C282Y homozygosity was 4.2 per 1000 in the general population (Table 6), 2.5 per 1000 in blood donors, and 161 per 1000 in family screening. Estimates for the prevalence of positive results for elevated TS and SF were relatively consistent among combined general population and blood donor studies, except for the broad range of results for elevated TS in general population females (40 to 94%). As might be expected, elevated TS estimates in blood donors tended towards the lower end of the general population range (56 to 70%) and in family members towards the higher end of the range (87.5%). SF levels were elevated in 54 to 58% of females and 58 to 76% of general population males, with slightly lower proportions in blood donors and elevated proportions (96%) in family members, an overall pattern similar to TS.

Table 5 Cross-sectional genotypic screening studies (12 studies)

Population screened | Range of prevalence of C282Y homozygotes | Elevated transferrin saturation | Elevated serum ferritin | Iron overload | Diabetes | Elevated LFTs | Fibrosis/ Cirrhosis
Health clinics (n=50,434) ^33,^ ^55,^ ^56^ | 3.7–5.7 per 1000 | M: 80% | M: 70 – 76% | Selected C282YY: 13/54 24% | 0 – 5.6% | ID | ID
Total C282YY studied: n=206 (156 not previously identified) | Avg: 4.1 per 1000 (calculated) | F: 40 – 41% | F: 54% | All C282YY: 13/102 12.8%
Blood donors (n=16,842) ^59^ – ^61^ | 1.5–3.1 per 1000 | M: >50 60 – 80% | M: 40–80% | ID | 0% | ID | ID
Total C282YY studied: n=42 | Avg: 2.5/1000 (calculated) | F: >45 27–67% | F: 0 – 9%
General population (n=3011) ^62^ | 5.3 per 1000 | >45 × 2 | 58% - (excludes those treated) | Selected C282YY: 4/7 (57.1%) | ID | ID | Cirrhosis or Fibrosis: Selected C282YY: 3/7 (43%) All C282YY: 3/12 (25%)
Total C282YY studied: n=16 (12 not previously identified) | | 93.8% | | All C282YY: 4/12 (33%) | | | Fibrosis: Selected C282YY: 2/7 All C282YY: 2/12 Cirrhosis: Selected C282YY: 1/7 All C282YY: 1/12
Voter rolls and employee screening (n=14,326) ^63^ – ^66^ | 4.0–4.7 per 1000 | >50–65 | 61.5% | Selected C282YY: 6/8 (75%) All C282YY: 6/13 (46%) | ID | ID | Fibrosis: Selected C282YY: 2/9(22%) All C282YY: 2/60 (3%)
Total C282YY studied: n=64 (60 not previously identified) | Avg: 4.5 per 1000 (calculated) | 65–84.6%
Family of probands(n=150) ^67^ | 161/1000 | 87.5% | 96% | ID | 16% (4/25) | ID | Cirrhosis = 2/25 (8%)
Total C282YY studied: n=25

LFT-liver function test; F-female; M-male; YY-C282Y/C282Y; ID-insufficient data; Avg-average; C282YY-C282Y/C282Y; Selected C282YY-% positives in only those tested; All C282YY: % positives in all C282YY.

* Patient consumed > 60 g of alcohol/day

Table 6 Summary estimates for genotypic screening yields from longitudinal and cross-sectional studies

LONGITUDINAL STUDIES | Prevalence of C282Y homozygotes | Elevated TS and SF in homozygotes | | Iron overload due to HH | Diabetes | Elevated Liver function tests | Fibrosis or cirrhosis
General population (2 studies)
Anderson, 2004 ^53^ | 2.5/1000 | M: 5/7 F: 9/16 (both combined) | | Selected C282YY:ND All C282YY: ND | All C282YY: 1/23 4.4% | ND | ND
Olynyk 2004 ^52^ | 4/1000 | M: 4/4 F: 2/6 (both tests combined) | | Selected C282YY: 5/6 All C282YY: 5/10 | ND | ND | Selected C282YY: 3/6 (1also drank) All C282YY: 3/10 (30%)
CROSS-SECTIONAL STUDIES | Prevalence of C282Y homozygotes | Elevated TS in C282Y homozygotes | Elevated SF in C282Y homozygotes | Iron overload due to HH | Diabetes | Elevated Liver function tests | Fibrosis or cirrhosis
General Population (7 studies)
(n=67,771) ^33,^ ^56,^ ^62^ – ^66^ Total C282YY studied: n=282 | 4.2/1000 | M: 75–94% F: 40–94% | M: 58–76% F: 54–58% | *Selected C282YY: 26/69 = 38% *All C282YY: 30/127 = 24% | All C282YY: max-5.6% min-0% | All C282YY: max-ND min-ND | **Cirrhosis or Fibrosis: Selected C282YY: 5/16 (31%) All C282YY: 5/72 (6.9%)
| | | | | | | **Fibrosis: Selected C282YY: 4/16 (25%) All C282YY: 4/72 (6%)
| | | | | | | **Cirrhosis: Selected C282YY: 1/16 (6%) All C282YY: 1/72 (1.4%)
Family History (1 study)
(n=150) ^67^ Total C282YY studied: n=25 | 161/1000 | M & F: 87.5% | M & F: 96% | All C282YY: ND | All C282YY: 16% | All C282YY: ND | Selected C282YY: ND
| 25/150 | 23/25 = 92% | | | | | All C282YY: 2/25 8%

Only included those ≥ 10.

* Data from Beutler, Burt, Distante, McDonnell, Olynyk.

** Data from Burt, Delatycki, Distante, Olynyk.

C282YY-C282Y/C282Y; F-female; M-male; ND- no data reported or not acceptable; Selected C282YY-% positives in only those tested; All C282YY-% positives in all C282YY; max-maximum; min-minimum

Iron overload was documented in 38% (range 24 to 75%) of 69 general population C282Y homozygotes selected for further evaluation. This translates to 24% (range 13 to 46%) of all C282Y homozygotes, assuming the absence of iron overload in those not further evaluated. One of two studies in family members reported iron overload in 51 C282Y homozygote family members. ^68^ Among 51 family members of probands, 86% of those evaluated (49% of all C282Y homozygote family members) had iron overload by hepatic criteria. The proportion of family members genotyped that were positive for C282Y homozygosity was not reported and so this study did not qualify to be reported in our summary tables. The other family study that qualified for summary tables did not report on iron overload in family members. ^67^

The prevalence of cirrhosis or fibrosis could be estimated for 72 C282Y homozygotes identified from the general population ^62,^ ^65,^ ^66^ and 25 C282Y homozygotes from family screening. ^67^ One of 16 patients biopsied had cirrhosis, while four had fibrosis. A minimum of 8% (2/25) of family-identified C282Y homozygotes had cirrhosis; fibrosis wasn't reported. In the general population, 0 to 5.6% of C282Y homozygotes had diabetes mellitus; one study reported a higher prevalence of diabetes mellitus (8.4%) in matched patients with non-homozygous genotypes. ^33^ Diabetes mellitus was present in 16% of C282Y homozygotes identified from families. In comparison to C282Y/C282Y family members, no compound heterozygote family members (C282Y/H63D, n=23) had hepatic cirrhosis of diabetes at the time of screening. ^67^

## Key Question 2. Does earlier therapeutic phlebotomy of individuals with primary iron overload due to HH reduce morbidity and mortality compared with treatment after diagnosis in routine clinical care?

We found no controlled studies of phlebotomy treatment in patients with hemochromatosis due to any cause, nor any studies that allowed comparison of early vs. delayed treatment. Three fair-quality case series of hemochromatosis patients reported objective measures before and after, or simply after, treatment ^25,^ ^26,^ ^69^ in six publications. ^22,^ ^23,^ ^25,^ ^26,^ ^69,^ ^70^ One retrospective observational survey ^71^ reported changes in symptoms after treatment among hemochromatosis patients identified through multiple outreach mechanisms (Appendix D Table 1). We excluded 61 other full-text articles, primarily due to study quality, size (fewer than 20 patients), or not containing primary data or relevant outcomes (Appendix D Table 2).

Summary of findings. Available treatment studies (three fair-quality case series of referral center patients) report on the survival experience of 447 total patients and the reduction in morbidity after treatment of 350 HC patients identified and treated over a 50-year period after 14.1 (±6.8) mean years of follow-up. ^25,^ ^26,^ ^69^ Only 85 of these patients had genotypically confirmed HH. Survival in diagnosed HC patients has improved over time and 10-year survival data in recently diagnosed patients does not differ from age- and sex- matched population controls. Similarly, survival in HH patients without cirrhosis at diagnosis does not differ from survival in population controls. Cirrhosis at diagnosis appears to confer a worse prognosis, although studies do not compare patients that are clearly similar. Comparisons of patients with less severe and more severe disease are biased by secular trends in disease severity at diagnosis, and perhaps secular differences in hemochromatosis treatment. Pre- and post-treatment liver biopsies suggest less reversibility in cirrhosis once it develops, compared with less severe liver disease, although these data come from uncontrolled observational studies. Some, but not all, symptoms appear to respond to treatment. Secular trends raise questions about the study relevance of most existing treatment studies and complicate their interpretation.

Individual studies. 336 patients from the two largest case series did not clearly have HH (i.e., and were identified over very long time periods 1937 to 1975 ^69^ and 1947 to 1991. ^26^ Another smaller study reported on 85 HH cases (56% probands and 44% family members), identified from 1958 to 1989. ^25^ Cumulative survival at five years was 87 to 93%, at 10 years was 77 to 81%, and at 20 years was 55 to 71%, ^25,^ ^26^ which was decreased compared with age-and-sex matched population controls. Fewer patients with HH had cirrhosis at diagnosis (32%), compared with unselected hemochromatosis patients (57 to 79%). Secular trends in disease severity and survival, however, were apparent over the time period these studies transpired (Figure 1). Those diagnosed in 1982 to 1991 showed better survival over 10 years of follow-up than the two groups diagnosed earlier (log-rank test, p≤0.05), and cumulative survival for HC patients diagnosed in 1982 to 1991 was not significantly reduced from rates expected for an age-and sex-matched population. ^26^ There was no significant difference, however, between survival in patients without cirrhosis at diagnosis and population controls. ^25^ Survival differences between patient subgroups (e.g., cirrhotic vs. non-cirrhotic, diabetics vs. non-diabetics), ^25,^ ^26^ or between all patients and historical controls, ^69^ were also reported, but are not reliable due to potential confounding by uncontrolled and unmeasured factors, such as time period of diagnosis, age at diagnosis, sex, excessive alcohol use, concomitant hepatitis, and dietary factors.

Figure 1. Secular trends in hemochromatosis associated morbidity. (Niederau, et al Long term survival in patients with hereditary hemochromatosis. Gast 110(4):1107–19, 1996) ^26^

Response to treatment was gauged by comparing pre-post symptoms and clinical features, including level of fibrosis on biopsy, for 185 unselected HC patients without regard to time of diagnosis. ^26^ Given the secular trends in symptoms and disease severity, the most meaningful data are those based on objective changes in liver biopsies by degree of fibrosis at baseline. Degree of fibrosis was: Stage 0 (pre-fibrosis, non-fibrosis, only septal fibrosis); Stage 1 (nonextensive portal fibrosis without bridging septa); Stage 2 (portal fibrosis with briding septa); Stage 3 (annual fibrosis with vascular disruption and cirrhosis). About half of patients with post-treatment repeat liver biopsies (n=93) had Stage 3 fibrosis/cirrhosis at diagnosis; 12 (13%) of these improved to Stage 2 fibrosis after treatment, none worsened, and 81 (87%) were unchanged. Among patients with Stage 2 fibrosis (n=39), about half (n=20) improved to Stage 1, none worsened, and about half (n=19) were unchanged. Among those with Stage 1 fibrosis (n=32), one-third showed reversal to pre-fibrosis (Stage 0), one worsened to Stage 2, and 21 (66%) were unchanged. Among those with no fibrosis at baseline (Stage 0), most (20/21) were unchanged, while one patient worsened to Stage 1 fibrosis. Very few patients' liver biopsies showed more severe fibrosis and liver biopsies after treatment, and liver pathology was unchanged for most patients, suggesting that treatment arrested disease progression. However, there is no untreated control group with which to compare these findings. For those with some level of liver fibrosis before treatment, 13 to 50% showed some improvement, with the lowest proportional improvement seen in those with the most advanced liver disease (Stage 3), suggesting that treatment is more effective in earlier disease. These findings, however, are based on qualitative histological readings and masking in outcome assessment was not clearly employed.

Cirrhosis (as opposed to fibrosis or normal liver) was significantly related to the risk of death in treated HH patients (adjusted relative risk 5.54, 95% C.I., 1.76, 17.47 (calculated)), controlling for arthritis and age at diagnosis. ^25^ This analysis did not control for date of diagnosis (occurring over 31 years) and presented sparse information on other possible confounders, such as alcohol intake.

Post-treatment liver biopsies showed no histological changes in 68 of 75 patients (91%), of whom 56 had cirrhosis and 12 had portal fibrosis, improvement from cirrhosis to portal fibrosis in five patients (7%), and progression from portal fibrosis to cirrhosis in two patients (3%). ^69^ Twelve patients (16%) accumulated enough iron after treatment to require a repeat course of venesection. The study reported comparisons to untreated historical controls (n=26), but these were excluded due to non-comparability between the two groups and potential confounding by secular trends in treatment improvements for severe disease, such as diabetes mellitus or hepatic failure.

One fair-quality retrospective and prospective case series assessed changes in nine signs and symptoms associated with HH six months after completion of phlebotomy treatment for biopsy-proved iron depletion in 183 primary care patients in Germany, diagnosed between 1947 and 1991. ^26^ Most (89%) were male, had cirrhosis or diabetes (57% and 48%), and were symptomatic at diagnosis. Six reasonably clear criteria for change were reported. Insulin-dependent diabetes mellitus was present in 25% of patients (46/183) and the daily insulin dose could be reduced in 41% of patients (19/46). Of 148 patients with elevated liver enzymes (ALT or AST), 108 (73%) showed improvement. Symptoms such as weakness/lethargy or abdominal pain were reported as absent after treatment in more than half of patients, which was not observed for arthralgias or loss of potency (30% and 19% resolved, respectively). Response to treatment was gauged by comparing pre- and post-symptoms and clinical features for patients regardless of time of diagnosis. Sign and symptom changes reported here are from an extremely heterogeneous group due to the secular trends in symptoms and disease severity at this study's presentation.

Response to treatment through retrospective patient recall was assessed in a large-scale study that attempted to survey known hemochromatosis patients in the United States (and to a lesser extent, Australia, U.K., and Canada) through direct mailings and solicitations through hemochromatosis-related organizations. ^71^ Respondents (2851/3562 mailings, 80%) were overwhelming white (99%), mostly male (62%), and had primarily been diagnosed after 1990 (70%). Most patients (65%) were diagnosed through family screening or an abnormal lab test. The frequency of several hemochromatosis-associated conditions (arthritis, diabetes mellitus, liver or gallbladder disease extreme fatigue) in U.S. survey respondents was quite similar to the frequency in the U.S. general population using NHANES data, with some excess reported in younger HC patients. Patients were asked to recall symptoms associated with their disease and the proportion that improved with therapy. Eighty-six percent of patients reported some or all symptoms improved with therapy, although one-third (33%) reported developing new symptoms despite therapy. Extreme fatigue improved in more than half of patients with that symptom, while depression and abdominal pain improved in 41% and 22%, respectively. Few reported improvements in impotence (13%) or joint pain (9%). How well these survey respondents represent all patients is not clear, because all responses were based on recall, and primary and secondary hemochromatosis did not appear to be distinguished (although the method of recruitment should have primary HC and HH). The absence of controls removes the possibility of assessing for a placebo effect or comparing non-specific symptom prevalence and changes over time.

## Key Question 3. Are there group(s) at increased risk for developing HH that can be readily identified prior to genetic screening?

We examined 55 full-text articles and excluded 45 studies from this question for reasons (Appendix E Table 2), such as not reporting relevant measures or results, addressing the wrong population, not using C282Y genotype to define the family risk group, non-included study designs, and quality. Two fair-to-good quality cross-sectional studies of family members and seven fair-to-good quality cross-sectional studies (in eight publications) of patients with signs or symptoms met our inclusion criteria. For family history risk determination, we included studies with C282Y-genotyped probands. ^67,^ ^72^ Besides family members of known C282Y homozygotes, other at-risk groups included patients with increased liver enzymes, fatigue, cardiac pacemakers, and those from specialty liver, endocrinology, and rheumatology clinics. ^56,^ ^73^ – ^79^ (See Appendix E Table 1 for full evidence table).

Summary of findings. Groups evaluated for increased risk of clinical hemochromatosis due to a higher prevalence of C282Y homozygosity included 434 family members of probands and 42,868 patients with signs or symptoms consistent with, but not specific for, iron overload taken from primary care or specialty settings. Family screening strategies identify the highest prevalence of undetected C282Y homozygotes (13 to 49%), particularly among siblings of probands and, perhaps, family members of clinically detected (as opposed to screen-detected) probands. Some patients selected for a variety of hemochromatosis-related symptoms and diseases have a higher prevalence of C282Y homozygosity compared with controls. Very selected chronic fatigue and arthralgia patients and hospitalized diabetic patients have a higher prevalence of C282Y homozygosity (5.7 to 5.8%), which is further increased (6.6 to 18.6%) when only those with elevated iron parameters are genotyped. Liver patients with elevated iron parameters also have an increased C282Y homozygous prevalence (7.1%). On the other hand, primary care patients selected for symptoms or signs consistent with HC have the same prevalence of C282Y homozygosity as controls, as do other types of selected patients. All null findings should be viewed with particular caution since many comparisons involved fewer than 250 patients per group which may seriously limit power to demonstrate a difference in prevalence since C282Y homozygosity in the general population is three to five per 1000.

Individual family-based studies. The prevalence of C282Y homozygosity among family members of probands is considerably higher than in the general population, but varies by how the probands were identified and their relationship to the family member. Among parents and adult siblings of HH probands (all C282Y/C282Y), 49% (59/121) of the relatives of those identified clinically were also C282Y homozygotes, compared with 15% (25/163) of the relatives of C282Y/C282Y probands identified from screening blood donors. ^72^ Fifty-nine percent of the 34 previously untested C282Y homozygous relatives of clinically identified probands had elevated iron parameters, as did 40% of the 25 homozygous relatives of screen-detected probands. However, these percentages may not be comparable as it is not clear what proportion of these 25 relatives were newly diagnosed. A higher proportion (53%) of relatives of clinically-identified probands had already been tested than of screen-detected probands (24%). Although 92% of eligible relatives of screen-detected probands and 85% of eligible relatives of clinically-identified probands participated, these data may not be entirely representative, as already-identified persons may have been more or less likely to participate. Among 112 first-, second-, and third-degree relatives of 61 unselected HC patients (73.8% of whom were C282Y homozygotes), 22.3% were C282Y homozygotes. ^67^ Siblings had the highest prevalence of C282Y homozygosity (33%), compared with parents, offspring, and other biological relatives (15.7%).

Individual studies in symptomatic patients. (Individual study details in Appendix E Table 1) A fair-quality, cross-sectional cohort study conducted after 1996 in France provided the most comprehensive data on the prevalence of the C282Y homozygous genotype among symptomatic patients. ^75^ Patients were selected from five different health care settings: 1) primary care (n=169 patients with an index sign or symptom for hemochromatosis); 2) rheumatology clinics (n=221 Rheumatoid factor negative patients with osteoporosis or arthropathy); 3) endocrinology clinics (n=121 diabetic patients hospitalized for diabetes-related complications); 4) referral medicine clinics (n=227 patients referred with chronic fatigue/arthralgia); and 5) 991 controls, a random sample of subjects attending a health appraisal clinic. The proportion of patients homozygous for C282Y ranged from 0 to 5.8% in various clinical populations, compared with 0.2% in the healthy volunteers. No difference in the prevalence of C282Y homozygosity was seen between controls or primary care patients with an index sign or symptom. C282Y homozygosity was significantly more prevalent in hospitalized diabetic patients from an endocrinology clinic (5.8%) and in referral medicine clinic patients with chronic fatigue and arthralgias (5.7%) (p<0.001) than in controls. In other studies, the prevalence of C282Y homozygosity appeared the same (women), or slightly higher (0.57% vs. 0.28% in men), in patients from a health appraisal clinic with elevated liver enzymes compared to those with normal enzymes. ^56^ Males, but not females, from the same clinic with chronic fatigue symptoms had a slightly higher (0.85%) prevalence of C282Y homozygosity, compared with those without symptoms (0.14%). Patients with a history of coronary heart disease appear to have the same or lower prevalence of C282Y homozygosity (0.17 to 0.28%) than those without symptoms. ^79^ Of 232 pacemaker patients, three had biopsy-proven iron overload, but HFE genotype was not available and HLA-typing showed only one-third to be consistent with genetic hemochromatosis. ^76^ Rheumatology patients appear to have a C282Y homozygosity prevalence similar to the general population. ^78^

A higher prevalence of C282Y homozygosity may be found in some groups of symptomatic patients when restricted to those who also have elevated iron parameters (Table 7). In 667 patients referred for investigation of liver disease, the prevalence of new HH cases by phenotypic screening was 2.8%; among those liver patients with increased TS levels (above 45%), 7.1% were homozygous for C282Y. ^73^ For hospitalized patients with diabetes and patients with chronic fatigue or arthralgias that were referred to specialists, C282Y homozygosity was higher in patients with TS above 40% and/or SF > 300 μg/L than in diseased patients without elevated iron measures (6.6% to 18.6% compared with 5.7% to 5.8%). The sensitivity of TS > 40% for detecting C282Y homozygosity in diabetics hospitalized for disease-related complications was 100%, but the specificity was 13%. In diabetic patients, the sensitivity of SF > 300 μg/L was 86% and the specificity was 56%. For patients referred for arthralgias and unexplained fatigue, TS > 40% and SF > 300 μg/L were about equally sensitive and specific for C282Y homozygosity (100% sensitive and 65 to 67% specific). Data are too sparse in rheumatology patients prescreened with elevated serum iron measures ^75^ and in a study of 88 patients with chronic fatigue syndrome. ^77^

Table 7 Prevalence of C282Y homozygotes in phenotypically screened high-risk populations

| Screening criteria | | % Positive (n) | | # C282Y/C282Y in screen positive patients | | % C282Y/C282Y in screen positive patients
Study | TS, % | SF, μg/L | TS | SF | TS | SF | TS | SF
Poullis, 2003 ^73^
Liver clinic (n=667) | > 45 | > 300 | 23% (156) | | 11/156 | | 7.1
Cadet, 2003 ^75^
Rheumatology (n=221) | > 45 | > 300 | 4% (9) | 4% (9) | ND | ND | ND | ND
Endocrinology (n=121) | > 40 | > 300 | 88% (106) | 46% (56) | 7/106 | 6/56 | 6.6% | 10.7%
Specialty setting: fatigue/arthritis (n=227) | > 40 | > 300 | 31% (70) | 33% (75) | 13/70 | 13/75 | 17.3% | 18.6%
Health appraisal-healthy volunteers (n=991) | > 40 | > 300 | 30% (293) | 6% (57) | 2/293 | 0/57 | 0 | 0.6%
Swinkels, 2002 ^77^
Chronic fatigue syndrome (n=88) | F: > 40 M: > 45 | F pre-menopause: > 80 F post-menopause: ≥ 190 M: > 280 | 7% (6) | 2% (2) | ND | ND | ND | ND

TS-transferrin saturation; SF-serum ferritin; ND-not determined-denominator too small; F-female; M-male