# Methods

## Key Questions

In conjunction with US Preventive Services Task Force leads and Agency for Healthcare Research and Quality (AHRQ) staff, we developed three explicit questions (see Table 1) with supporting definitions (Table 2) to capture the critical evidence in making a recommendation for HH as a new screening topic. Key Question 1 examines the development of clinical hemochromatosis among C282Y/C282Y homozygotes (penetrance). Key Question 2 addresses intermediate and health outcomes of therapeutic phlebotomy treatment for asymptomatic primary iron overload due to HH, emphasizing the incremental benefit of earlier treatment. Key Question 3 examines whether there are identifiable groups at high-risk for developing HH for possible targeted genetic screening.

Key questions

1 Among those with a homozygous C282Y genotype, what is the risk of developing clinical hemochromatosis?
2 Does earlier therapeutic phlebotomy of individuals with primary iron overload due to HH reduce the morbidity and mortality compared with treatment after diagnosis in routine clinical care?
3 Are there groups at increased risk for developing HH that can be readily identified prior to genetic testing?

Definitions

[underlined: Asymptomatic] : with no or only general and vague symptoms like arthralgias, emotional distress, fatigue, abdominal pain and non-specific signs, such as elevated liver function tests.

[underlined: Biochemical screening] : measurement of transferrin saturation and/or serum ferritin to screen for primary iron overload.

[underlined: Clinical hemochromatosis] : diagnosed liver disease (fibrosis, cirrhosis, liver failure, hepatocellular carcinoma), cardiomyopathy, diabetes mellitus, or arthropathy in the presence of primary iron overload.

[underlined: Elevated iron parameters] : increased levels of body iron as reflected by elevations in serum transferrin saturation or serum ferritin.

[underlined: Groups at increased risk for developing clinical hemochromatosis] : includes asymptomatic individuals who can be identified by virtue of an associated factor or sign and who might be the focus of a targeted genetic screening program. Factors or signs could include age, sex, ethnicity, family history of iron overload or clinical hemochromatosis, increased liver function tests. Does not include those with existing disease (diabetes mellitus, cirrhosis, cardiomyopathy) where the effort is to detect hemochromatosis in order to treat the disease, as this is tertiary prevention.

[underlined: Iron overload (IO)] : excess deposition of iron in liver diagnosed by liver biopsy or increased total body mobilizable iron diagnosed by quantitative phlebotomy. Criteria for diagnosis is liver biopsy specimen with hepatic iron index of 1.9, with or without fibrosis. In quantitative phlebotomy, iron overload (IO) represents the removal of > 4 grams of mobilizable iron to reach biochemical indicators of iron depletion. This corresponds approximately to > 90 μmol/g of hepatic iron or at least “moderate” iron overload (on scale of normal, mild IO, moderate IO, substantial IO and severe IO). “Iron overload” not meeting this standard may be considered possible or provisional primary iron overload.

[underlined: Genotypic screening] : detecting those with, or at risk for, developing iron overload or clinical hemochromatosis through genotyping the HFE gene to detect C282Y homozygosity.

[underlined: Hemochromatosis (HC)] : term used variously in the literature, but here to mean manifest disease determined to be due to excess body iron, but not clearly fitting more precise etiologic definitions.

[underlined: Hereditary hemochromatosis (HH)] : IO or clinical hemochromatosis due to C282Y homozygosity

[underlined: Morbidity] : organ damage that results in physical disability over and above that not seen in the absence of iron overload.

[underlined: Phenotypic screening] : detecting those with or at risk for developing clinical hemochromatosis through biochemical screening using serum ferritin and/or transferrin saturation.

[underlined: Primary iron overload] : due to an inherent, inherited defect in iron regulation.

[underlined: Screening population:] refers to a group of populations of individuals who are identified and tested in a manner that is not related to their symptoms - i.e. they are not identified through disease signs or symptoms. A screening population can be identified by their relationship to a proband, as long as their symptoms did not bring them to the attention of the researchers.

[underlined: Targeted screening] : screening those identified as high-risk for developing hemochromatosis as opposed to general population screening.

[underlined: Therapeutic phlebotomy] : the process of repeatedly drawing blood until iron parameters are within normal limits. Typically treatment schedule is one unit (500 mL) of blood, biweekly until serum ferritin < 20μg/l. Maintenance therapy of 3–4 units/yr is common.

[underlined: Unselected hemochromatosis patients] : those with primary hemochromatosis not clearly due to C282Y homozygosity but with secondary causes eliminated. A term created to describe a category of patients with genetic disease not clearly due to C282Y.

[underlined: Wild type] : in HFE genotyping, typically refers to individuals who do not have C282Y and/or H63D alleles, the alleles most commonly tested.

## Literature Retrieval

We developed literature search strategies and terms for each Key Question (KQ) (Appendix A) and conducted four separate literature searches (for KQs 1, 2, 3, and background) in Medline, CINAHL, and the Cochrane library. Literature searches were supplemented with source material from experts in the field and from examining the bibliographies of included studies. A single investigator reviewed abstracts, with all excluded abstracts reviewed by a second investigator for all KQs. Inter-reviewer discrepancies during the dual review process were resolved by consensus.

### Abstract/Article Review and Data Abstraction

Using inclusion criteria developed for each key question (described in Appendix A), we reviewed 1886 abstracts for inclusion in all KQs. Literature searches were focused for each KQ, but were reviewed with all KQs in mind. We reviewed 133 full-text articles for KQ1, 67 articles for KQ2, and 55 articles for KQ3. Two investigators quality rated all included articles and those excluded for quality-reasons, using the USPSTF criteria (Appendix B). Listings of excluded articles, with reasons, for each by KQ are in Appendices C, D, and E.

### Critical Appraisal of Included Studies

Using methods of the USPSTF, ^50^ we critically appraised studies using quality criteria specific to their design (Appendix B). To augment criteria provided for non-randomized treatment effectiveness studies, we added criteria from the Non-Randomized Studies Methods Group of the Cochrane Collaboration. ^51^ We eliminated any case series or non-randomized comparative treatment study that used a non-systematic method of case ascertainment. We critically considered the comparability of constructed comparison groups, particularly concerning confounding factors (age, sex, alcohol intake, population prevalence of C282Y homozygosity, and comorbid liver disease) and secular trends in disease diagnosis and medical care. We eliminated those with possible serious biases.

## Terminology and Definitions

We found very inconsistent uses of terminology regarding hemochromatosis in the literature, complicated by evolution in the understanding of its pathogenesis, hereditary components, and secondary causes over the last 20 to 30 years, and by disagreements among experts. We adopted the set of terms in Table 2 for use in this review.

Similarly, diagnostic and screening criteria also varied markedly. After reviewing several textbooks, the Hemochromatosis and Iron Overload Screening (HEIRS) study protocol, and the screening and diagnostic approaches used in several recent, good-quality studies, we established a priori screening and diagnostic criteria for elevated iron parameters and iron overload due to HH to guide our review and to establish comparability between studies (see Table 3).

Table 3 Screening and diagnostic criteria for iron overload

Term/Test | Males | Females
Screen-positive for Elevated Iron Parameters
Transferrin Saturation (TS) ^1^ – ^3^ | >50% | >45%
Serum Ferritin (SF) ^2,^ ^4^ | >300μg/L | >200μg/L
Possible Iron Overload (PIO)
(Repeat TS OR | > 50% | >45%
Repeat SF OR | >300μg/L | >200μg/L
Initial >TS and >SF) AND Clinical exam
Provisional Primary Iron Overload (PPIO) ^2^
Repeat TS and SF both increased and not due to liver disease, inflammation, or secondary causes of IO
Documented Iron Overload (IO) ^2^
Meets all the PPIO criteria and increased body iron stores by one or more of:; - Hepatic iron concentration (from biopsy) (HIC); - Iron removed to reach iron depletion (phlebotomy); - Histology; - Hepatic iron index (HII); - Hepatic iron staining | - ≥ 90 μm/g, ≥ 5000 μg/g dry wt; - >4 g iron removed; - histology suggestive of HC [underlined: and] HII ≥ 1.9; - 3+, 4+

1 Feldman M, Tschumy WO, Friedman LS, and Sleisenger MH. Sleisenger & Fordtran's Gastrointestinal and Liver Disease, Elsevier, 2002.

2 McLaren CE, Barton JC, Adams PC, Harris EL, Acton RT, Press N, Reboussin DM, McLaren GD, Sholinsky P, Walker AP, Gordeuk VR, Leiendecker-Foster C, Dawkins FW, Eckfeldt JH, Mellen BG, Speechley M, Thomson E. Hemochromatosis and Iron Overload Study Research Investigators. Hemochromatosis and Iron Overload Screening (HEIRS) study design for an evaluation of 100,000 primary care-based adults. American Journal of the Medical Sciences. 2003;325(2):53-62. [pmid: 12589228].

3 Tavill S. American Association for the Study of Liver Diseases, American College of Gastroenterology, and American Gastroenterological Association. Diagnosis and management of hemochromatosis. Hepatology. 2001;33(5):1321-8. [pmid: 11343262].

4 Powell LW, George DK, McDonnell SM, Kowdley KV. Diagnosis of hemochromatosis. Annals of Internal Medicine. 1998;129(11):925-31. [pmid: 9867744].

## Data Synthesis

We evaluated whether our review identified adequate data to create one or more outcomes tables to illustrate the expected yield from screening using an approach adapted from a previous report. ^43^ For this approach, we considered data for two different screening populations (general population and family-based) for genotypic screening followed by phenotypic screening and phenotypic screening followed by genotypic screening. Phenotypic screening approaches included TS (single or repeated) and SF measured singly, in sequence, or in combination. Genotypic screening required HFE genotyping and determination of C282Y homozygosity. Insufficient data across these parameters were available to create a reliable outcomes table for either screening approach. Few studies reported results for genotype, iron parameters, and iron overload, generating very small numbers for within-study morbidity estimates. We therefore summarized screening data in tables as described below.

Summary Tables. Data for family-based and general populations were kept separate. Data for the general population were categorized into subgroups and combined, where they were sufficiently similar. To evaluate the extent and adequacy of data for each parameter, and to combine data across studies, we selected data from studies included in our review to meet minimum a priori criteria (developed from the literature) for three parameters (Tables 2 and 3): 1) screen positive for elevated iron parameters; 2) documented iron overload; and 3) morbidity due to clinical hemochromatosis. For iron overload and morbidity, we calculated and reported two proportions (selected and all). Among those selected, we reported the positives among those who were actually tested for iron overload or morbidity (maximum penetrance) and second for all who screened positive in the first screening step (minimum penetrance). Within each screening approach, we evaluated whether results were similar enough to combine across studies and, when they were, we quantitatively combined study results for each parameter to generate a single point estimate for that parameter. Some general population subgroups were kept separate (blood donors). Other general population groups were summarized within categories (health clinics, voter roles, and employee screening) and across categories (all combined as general population). We reported a range of results for any parameter for which individual study results were too different to be meaningfully combined. We did not include individual study results with 10 or fewer subjects in the denominator to define a range, but did include these results if they could be combined with other results in a single parameter estimate. Study results were reported as raw numbers for denominators of 10 or less.

## External Review Process

The USPSTF appointed four liaisons to advise the Oregon Evidence-based Practice Center in formulating and reporting this focused systematic review. An additional set of outside experts provided advice in the review formulation stage and gave us comments on a draft version of the evidence synthesis.