# Introduction

Screening for Hereditary Hemochromatosis is a topic that has not been previously considered by the United States Preventive Services Task Force (USPSTF) for a possible recommendation as a clinical preventive service for primary care clinicians. This product is a pilot approach to systematically review the sufficiency of evidence for a focused (as opposed to comprehensive) set of key questions related to two main USPSTF screening criteria: the burden of suffering and the potential effectiveness of a preventive intervention, therapeutic phlebotomy. ^1,^ ^2^ The USPSTF considers conditions of major significance that are relatively common in the U.S. to be candidates for preventive interventions, such as screening. ^2^ Also, for a condition to be a candidate for a USPSTF screening recommendation, there must be evidence that persons with the condition detected early have a better clinical outcome that those detected without screening. ^1^ Key questions for this review were limited to what the USPSTF judged to be critical evidence gaps in establishing these requirements. Key questions were constructed and applied using strict and consistent definitions of disease, which are described in more detail below. The resulting report is intended to demonstrate evidence sufficiency or insufficiency as its primary aim, and thus does not have the usual breadth associated with a USPSTF systematic evidence review.

## Condition Definition

Hemochromatosis (HC) was originally thought to be a rare idiopathic disorder characterized by end-stage disease (cirrhosis, diabetes, and bronzed skin), but is now recognized as often having a hereditary component due to an autosomal recessive inherited disorder of iron metabolism. ^3^ In HC, body iron accumulates and can lead to iron overload. ^4^ In iron overload, excess iron is deposited in the liver, pancreas, heart, joints, and endocrine glands, resulting in tissue damage that may lead to one or more disease conditions (e.g., cirrhosis, diabetes, increased skin pigmentation, heart failure, arthropathy, and impotence). ^4^ – ^6^ Iron overload can be primary (as in hereditary hemochromatosis) or secondary (e.g., due to anemias with inefficient erthropoeisis or repeated blood transfusions). ^7^

Genetic understanding of hereditary hemochromatosis (HH) was advanced in 1996 when Feder identified two base pair alterations, termed C282Y and H63D, of the HFE gene on the region of HLA-A on chromosome 6 in hereditary hemochromatosis. ^8^ C282Y homozygosity is now recognized as the most common genotype in hereditary hemochromatosis. ^9^ Estimates are that 82 to 90% of HH among Caucasians occurs in C282Y/C282Y homozygotes. ^10^ The other 10 to 18% of cases appear to be due to environmental factors and/or other genotypes. There are other HFE- and non-HFE-related genetic mutations associated with HH in a small minority of cases, ^4^ but no other genotypes appear to be nearly as predisposed to developing HH as HFE C282Y/C282Y. ^3,^ ^9^

HFE mutations are fairly common in the U.S. population. In Caucasians, 4.4 per 1000 are homozygous and 1 in 10 are heterozygous for (carriers of) the HFE C282Y mutation. ^6,^ ^11^ The frequency of C282Y homozygosity is much lower among Hispanics (0.27 in 1000), Asian Americans (<0.001 per 1000) and Pacific Islanders (0.12 per 1000), and Blacks (0.14 per 1000). ^11^ Individuals homozygous for the C282Y genotype can be characterized in one of four general stages: genetic predisposition without any other abnormality; iron overload without symptoms; iron overload with early symptoms; iron overload with organ damage, especially cirrhosis. ^4^ The availability of genotyping has made it possible to identify those with the susceptible genotype with little or no evidence of disease.

Clinically recognized HH is twice as common in males and occurs predominantly in Caucasian populations. ^12^ While the natural history is not well understood, the condition appears to have a long latent period. Biochemical expression appears to vary widely among individuals, ^13^ and iron accumulation and disease expression are modified by environmental factors, such as blood loss from menstruation or donation, alcohol intake, diet, and comorbid disease (e.g. viral hepatitis). ^14,^ ^15^ If symptomatic organ involvement develops, it is generally in mid-life with non-specific signs and symptoms (e.g., unexplained fatigue, joint pain, abdominal pain). ^3^ Age of onset is delayed in females, ^16^ perhaps due to blood loss through menstruation. ^3^ The liver is the first target organ thought to be affected by iron accumulation, ^17^ which is central to both diagnosis and prognosis. ^13^ While a clinical diagnosis is sometimes based on serum iron studies and clinical evaluation, documentation of iron overload relies on one of two methods: quantitative phlebotomy (repeated phlebotomy to iron depletion) with calculation of the amount of iron removed; or liver biopsy with determination of quantitative hepatic iron. ^18^ Although liver biopsy was once essential to the diagnosis, it is currently used more as a prognostic tool. ^19^ A hepatic iron concentration above 283 micromoles per gram (reference range = 0 to 35 micromoles per gram dry weight) is associated with cirrhosis in C282Y homozygotes. ^20^ Many patients with much higher levels, however, do not have cirrhosis. ^13^ Even in the absence of systemic iron overload, iron accumulates when the liver is inflamed or cirrhosed due to other causes (e.g., alcoholic steatohepatitis, transfusion and chronic hemolytic disorders, or chronic viral hepatitis). ^21^

Cirrhosis is a late-stage disease development and has been reported to shorten life expectancy. ^22^ – ^25^ Cirrhosis is also a risk factor for hepatocellular carcinoma ^13^ and typically occurs between the ages of 40 to 60 years. ^6^ Cirrhosis is less frequently a finding at diagnosis of clinical hemochromatosis than in the past, ^26^ and cirrhosis prevention would be a major goal of screening and treatment. ^27^

## Prevalence and Burden of Disease

The general population prevalence of HC is difficult to establish due to its long, variable preclinical period and to lack of a consistent “case” definition for disease. The prevalence of “cases of HC” defined as biochemical (elevated serum iron indices) will be more prevalent than cases based on documented iron overload, with or without clinical signs and symptoms; the lowest prevalence will be for cases based on diagnosed disease (cirrhosis, diabetes). ^28^ Experts have recommended defining an iron overload state as distinct from HC, ^4^ and this provides an objective, although not universally accepted, standard for “early disease” based on documented increases in body iron stores. ^28^

Available population-based studies have generally used case definitions based on clinical diagnoses of HC (or diagnoses compatible with HC) to estimate the population-level disease burden for this condition. A total of 79,850 HH-associated hospitalizations (2.3 per 100,000 residents) were projected in the U.S. population over 18 years (1979 to 1997); annual rates could not be reliably calculated. ^29^ Out of 29 million deaths from 1979 to 1992, a total of 4858 (0.017%) were consistent with HC as an underlying cause. ^12^ Age-adjusted mortality rates for HC-consistent deaths increased from 1.2 per million U.S. residents in 1979 to 1.8 per million U.S. residents in 1992. These rates were about twice as high in males than females and in whites than non-whites. These two estimates were based on similar ICD-9 codes, but suggest a disease prevalence that is much lower than the prevalence of associated genetic mutations, which has fueled debate about disease penetrance (the proportion of those with the genotype expressing the phenotype) in HH. These statistics are probably underestimates, primarily due to underdiagnosis, ^30^ but the extent of this underestimation is not clear.

The prevalence of HC-attributable morbidities (e.g., cirrhosis, diabetes, arthralgias, and fatigue or other symptoms) may help estimate the size of the burden due to undiagnosed disease, particularly since diagnosis may commonly be delayed due to the non-specific nature of HC-related signs and symptoms. ^31^ However, since these signs and symptoms are also quite prevalent and non-specific to HC, relevant evidence must establish their prevalence due to iron overload or their excess prevalence in association with iron overload compared with controls. Recent general population and clinical population studies suggest some morbidities possibly associated with unrecognized HC are more prevalent in newly detected cases than would be expected. Compared with controls, 297 previously undetected, middle-aged genotypic hemochromatosis cases (HH: homozygous for C282Y), and 269 previously undetected, middle-aged phenotypic hemochromatosis cases (unselected HC: repeated high serum transferrin saturation (TS) and high serum ferritin (SF) without other known causes), had a higher prevalence of diagnosed osteoarthritis, knee complaints, hypothyroidism, and use of antihypertensive or thyroid replacement medications than sex- and age-specific controls. ^32^ However, general health, mental health, and 52 other questionnaire- and clinical-exam-based measures of cardiovascular, respiratory, and liver diseases were not statistically different in cases than controls. This study did not statistically adjust for multiple comparisons. In another cross-sectional comparison of 124 C282Y screen-detected adult homozygotes with 22,394 wild type/wild type genotypic controls, common symptoms (chronic fatigue, joint symptoms, impotence, limited general health) and signs (diabetes) were no more frequent in C282Y homozygotes than controls. ^33^ While the relative risk of doctor-diagnosed liver problems or hepatitis was increased (RR 2.1, 95% CI 1.1, 4.0), the proportion of C282Y homozygotes with liver problems was modest (10%). Similarly, in the HEIRS study, C282Y homozygotes had an increased odds of self-reported liver disease (3.28, 95% CI, 1.49, 7.22) compared with wild-type controls however, almost one-fourth were not newly identified. ^11^

The meaning of population-based studies, such as these, for establishing the prevalence and disease burden, is debated, and other types of evidence are cited in the debate. Experts also argue over biases from observational studies, emphasizing problems with under-diagnosis, study populations used in available studies, estimates from uncontrolled studies, and patients selected for controlled comparisons. ^34^ – ^40^

## Rationale for Population Screening

Screening for HC or iron overload is theoretically attractive and has been widely discussed in the last 10 to 15 years, with renewed interest and a focus on HH since the discovery of the HFE mutations. ^4,^ ^41^ – ^44^ Indeed, many have claimed that HH meets all the criteria for screening set forth by the USPSTF and other prominent organizations: ^7,^ ^16,^ ^45^ – ^47^ the genetic condition predisposing to iron overload is prevalent; treatment with periodic phlebotomy appears to be a safe and effective way to reduce progression in those with early disease; commonly available laboratory tests appear to be sensitive in identifying iron overload in its early phases (enhanced by availability after the mid-1990s of genotyping to identify HH); and little harm should result from a minimally invasive screening usually based on blood or other readily available tissues. Based on these factors, population screening for HH using biochemical (phenotypic screening) and/or genetic tests (genotypic screening) would appear to have a high net benefit, where the benefits substantially outweigh harms.

Although HH appears to be ideal for population screening ^48^ and a “new paradigm for genetics and public health,” ^42^ inadequacies in the evidence supporting genetic screening for HH have precluded wide-spread calls for population-based screening. ^4,^ ^9,^ ^42,^ ^48^

A major source of uncertainty lies in the natural history and burden of illness, as introduced above, which must be understood as causing significant preventable disease in the U.S. ^2^ How much disease is actually caused by HFE mutations? This has been repeatedly identified as the most critical evidence issue preventing population screening, relating to whether sufficient data exist to determine the proportion of individuals identified through genetic testing who will develop clinically significant disease. ^3,^ ^4,^ ^48^

Screening programs must be based on the benefits of early detection and treatment beyond the health improvement that would be seen if diagnosis and treatment occurred during the usual process of care. ^2^ To support population screening, treatment must not only be accessible, safe, cheap, and effective, but treatment initiated earlier than currently occurs after disease identification must also show clear benefit. The second major uncertainty lies in the evidence to support a benefit of early treatment. Does therapeutic phlebotomy treatment, initiated through earlier identification of those with HH, lead to better outcomes?

## Focused Systematic Review Aims

In this focused systematic review, we addressed the adequacy of current evidence to answer the two critical uncertainties central to making primary-care-based screening for HH eligible for recommendation in the general population. We also considered the evidence supporting the identification of high-risk groups for screening.

Although there are multiple etiologies for both iron iron overload and HC, this review focused on the evidence regarding penetrance in hereditary disease and the extent and progression of disease in persons identified as having a HH susceptibility genotype. We focused on hereditary HFE-associated hemochromatosis due to C282Y homozygosity in persons of Northern European descent, which is the most prevalent form of HH in the United States. Other HFE and non-HFE genetic mutations are much rarer causes of hemochromatosis ^49^ and data for their disease association are more sparse than for C282Y homozygosity. ^9^ Thus, we did not think that the sufficiency of evidence for this topic would be enhanced by also considering other causes of HH, and their inclusion would only further complicate the issue.