# References

1 Patel H. Canadian Task Force on Preventive Health C. Preventive health care, 2001 update: screening and management of developmental dysplasia of the hip in newborns. Can Med Assoc Jl. 2001;164(12):1669-1677.
2 Lehmann HP, Hinton R, Morello P, et al. Developmental dysplasia of the hip practice guideline: technical report. Committee on Quality Improvement, and Subcommittee on Developmental Dysplasia of the Hip. Pediatrics. 2000;105(4):E57. [pmid: 10742378].
3 Clinical practice guideline: early detection of developmental dysplasia of the hip. Committee on Quality Improvement, Subcommittee on Developmental Dysplasia of the Hip. American Academy of Pediatrics. Pediatrics. 2000;105(4 Pt 1):896–905.
4 Bialik V, Bialik GM, Blazer S, et al. Developmental dysplasia of the hip: a new approach to incidence. Pediatrics. 1999;103(1):93-99. [pmid: 9917445].
5 Gardiner HM, Clarke NM, Dunn PM. A sonographic study of the morphology of the preterm neonatal hip. J of Pediatr Ortho. 1990;10(5):633-637.
6 Barlow T. Early diagnosis and treatment of congenital dislocation of the hip. J Bone Joint Surg. 1962;44:292-301.
7 Omeroglu H, Koparal S. The role of clinical examination and risk factors in the diagnosis of developmental dysplasia of the hip: a prospective study in 188 referred young infants. Arch Ortho Trauma Surg. 2001;121(12):7-11.
8 Yiv BC, Saidin R, Cundy PJ, et al. Developmental dysplasia of the hip in South Australia in 1991: prevalence and risk factors. J Paediatr Child Health. 1997;33(2):151-156. [pmid: 9145360].
9 Chan A, McCaul KA, Cundy PJ, et al. Perinatal risk factors for developmental dysplasia of the hip. Arch Dis Child. 1997;76(2):F94-100.
10 Standing Medical Advisory Committee, Standing Nursing and Midwifery Advisory Committee Working Party for the Secretaries of State for Social Services and Wales. Screening for the detection of congenital dislocation of the hip. Arch Dis Child. 1986;61(9):921–926.
11 Barlow T. Early diagnosis and treatment of congenital dislocation of the hip in the newborn. Proc R SocMed. 1966;59:1103-1106.
12 Ortolani M. Congenital hip dysplasia in the light of early and very early diagnosis. Clin Orthop Relat Res. 1976(119):6–10.
13 Baronciani D, Atti G, Andiloro F, et al. Screening for developmental dysplasia of the hip: from theory to practice. Collaborative Group DDH Project. Pediatrics. 1997;99(2):E5. [pmid: 9099762].
14 Bialik V, Bialik GM, Wiener F. Prevention of overtreatment of neonatal hip dysplasia by the use of ultrasonography. J Pediatr Orthop, Part B. 1998;7(1):39-42.
15 Andersson JE. Neonatal hip instability: results and experiences from ten years of screening with the anterior-dynamic ultrasound method. Acta Paediatrica. 2002;91(8):926-929. [pmid: 12222717].
16 Giannakopoulou C, Aligizakis A, Korakaki E, et al. Neonatal screening for developmental dysplasia of the hip on the maternity wards in Crete, Greece. Correlation to risk factors. Clin Exper ObstGyn. 2002;29(2):148-152.
17 Vitale MG, Skaggs DL. Developmental dysplasia of the hip from six months to four years of age. J Am Acad Orthop Surg. 2001;9(6):401-411. [pmid: 11730331].
18 Slavin R. Best practice synthesis: an alternative to meta-analytic and traditional reviews. Educ Res. 1986;15:5-11.
19 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
20 McDonagh M, Carson S, Ash J, al. e. Hyperbaric oxygen therapy for brain injury, cerebral palsy, and stroke. Evidence Report/Technology Assessment No. 85 Rockville, MD: Agency for Healthcare, Research, and Quality; 2003 September. AHRQ Publication No. 04-E003.
21 Rosendahl K, Markestad T, Lie RT. Ultrasound screening for developmental dysplasia of the hip in the neonate: the effect on treatment rate and prevalence of late cases. Pediatrics. 1994;94(1):47-52. [pmid: 8008537].
22 Tredwell SJ, Bell HM. Efficacy of neonatal hip examination. JPediatr Ortho. 1981;1(1):61-65.
23 Dunn PM, Evans RE, Thearle MJ, et al. Congenital dislocation of the hip: early and late diagnosis and management compared. ArchDisChild. 1985;60(5):407-414.
24 Yngve D, Gross R. Late diagnosis of hip dislocation in infants. J Pediatr Ortho. 1990;10(6):777-779.
25 Macnicol MF. Results of a 25-year screening programme for neonatal hip instability. J Bone Joint Surg - British Volume. 1990;72(6):1057-1060.
26 Place MJ, Parkin DM, Fritton JMKS. Effectiveness of neonatal screening for congenital dislocation of the hip. Lancet. 1978;2(8083):249-250. [pmid: 79042].
27 MacKenzie IG, Wilson JG. Problems encountered in the early diagnosis and management of congenital dislocation of the hip. J Bone Joint Surg - British Volume. 1981;63-B(1):38-42.
28 Sanfridson J, Redlund-Johnell I, Uden A. Why is congenital dislocation of the hip still missed? Analysis of 96,891 infants screened in Malmo 1956-1987. Acta Orthopaedica Scandinavica. 1991;62(2):87-91. [pmid: 2014732].
29 Catford JC, Bennet GC, Wilkinson JA. Congenital hip dislocation: an increasing and still uncontrolled disability?. Br Med J (Clin Res Ed). 1982;285(6354):1527-1530.
30 Patterson CC, Kernohan WG, Mollan RA, Haugh PE, Trainor BP. High incidence of congenital dislocation of the hip in Northern Ireland. Paediatr Perinat Epidemiol. 1995;9(1):90-97. [pmid: 7724416].
31 Godward S, Dezateux C. Surgery for congenital dislocation of the hip in the UK as a measure of outcome of screening. MRC Working Party on Congenital Dislocation of the Hip. Medical Research Council. Lancet. 1998;351(9110):1149-1152. [pmid: 9643684].
32 Chan A, Cundy PJ, Foster BK, et al. Late diagnosis of congenital dislocation of the hip and presence of a screening programme: South Australian population-based study. Lancet. 1999;354(9189):1514-1517. [pmid: 10551498].
33 Andersson JE, Oden A. The breech presentation and the vertex presentation following an external version represent risk factors for neonatal hip instability. Acta Paediatr. 2001;90:895-898. [pmid: 11529538].
34 Artz TD, Lim WN, Wilson PD, Levine DB, Salvati EA. Neonatal diagnosis, treatment and related factors of congenital dislocation of the hip. Clin Orthop Relat Res. 1975(110):112–136.
35 Bache CE, Clegg J, Herron M. Risk factors for developmental dysplasia of the hip: ultrasonographic findings in the neonatal period. J Pediatr Ortho, Part B. 2002;11(3):212-218.
36 Boeree NR, Clarke NM. Ultrasound imaging and secondary screening for congenital dislocation of the hip. J Bone Joint Surg - British Volume. 1994;76(4):525-533.
37 Boere-Boonekamp MM, Kerkhoff TH, Schuil PB. Early detection of developmental dysplasia of the hip in The Netherlands: the validity of a standardized assessment protocol in infants. Am J Public Health. 1998;88(2):285-288. [pmid: 9491024]. [pmcid: 1508179].
38 Goss PW. Successful screening for neonatal hip instability in Australia. J PaediatrChild Health. 2002;38(5):469-474.
39 Holen KJ, Tegnander A, Terjesen T, et al. Ultrasonographic evaluation of breech presentation as a risk factor for hip dysplasia. Acta Paediatr. 1996;85(2):225-229. [pmid: 8640055].
40 Jones DA. Importance of the clicking hip in screening for congenital dislocation of the hip. Lancet. 1989;1(8638):599-601. [pmid: 2564121].
41 Miranda L, Palomo JM, Monzonis J, et al. Prevention of congenital dislocation of the hip in the newborn. J Pediatr Ortho. 1988;8(6):671-675.
42 Sahin F, Akturk A, Beyazova U, et al. Screening for developmental dysplasia of the hip: results of a 7-year follow-up study. Pediatr Int. 2004;46(2):162-166. [pmid: 15056242].
43 Walter RS, Donaldson JS, Davis CL, et al. Ultrasound screening of high-risk infants. A method to increase early detection of congenital dysplasia of the hip. Am J Dis Child. 1992;146(2):230-234. [pmid: 1733155].
44 Paton RW, Srinivasan MS, Shah B, et al. Ultrasound screening for hips at risk in developmental dysplasia. Is it worth it?. J Bone Joint Surg - British Volume. 1999;81(2):255-258.
45 Riboni G, Bellini A, Serantoni S, et al. Ultrasound screening for developmental dysplasia of the hip. Pediatr Radiol. 2003;33(7):475-481. [pmid: 12750862].
46 Rosenberg N, Bialik V, Norman D, et al. The importance of combined clinical and sonographic examination of instability of the neonatal hip. Int Ortho. 1998;22(3):185-188.
47 Rosendahl K, Markestad T, Lie RT. Developmental dysplasia of the hip. A population-based comparison of ultrasound and clinical findings. Acta Paediatr. 1996;85(1):64-69. [pmid: 8834982].
48 Elbourne D, Dezateux C, Arthur R, et al. Ultrasonography in the diagnosis and management of developmental hip dysplasia (UK Hip Trial): clinical and economic results of a multicentre randomised controlled trial. Lancet. 2002;360(9350):2009-2017. [pmid: 12504396].
49 Holen KJ, Tegnander A, Bredland T, et al. Universal or selective screening of the neonatal hip using ultrasound? A prospective, randomised trial of 15,529 newborn infants. J Bone Joint Surg - British Volume. 2002;84(6):886-890.
50 Bjerkreim I, Arseth PH. Congenital dislocation of the hip in Norway. Late diagnosis CDH in the years 1970 to 1974. Acta Paediatr Scan. 1978;67(3):329-332.
51 Quinland WR, Brady PG, Regan BF. Late diagnosis of congenital dislocation of the hip. Ir Med J. 1978;71(13):447-449. [pmid: 700990].
52 Glass A, Dunningham TH. Capsular arthroplasty of the hip for congenital dislocation. Isr J Med Sci. 1980;16(4):328-332. [pmid: 7390786].
53 Kepley RF, Weiner DS. Treatment of congenital dysplasia-subluxation of the hip in children under one year of age. J Pediatr Ortho. 1981;1(4):413-418.
54 Late diagnosis of hip dislocation. Lancet. 1983;2(8342):145.
55 Heikkila E, Ryoppy S, Louhimo I. Late diagnosis in congenital dislocation of the hip. Acta Ortho Scan. 1984;55(3):256-260.
56 Lehmann EC, Street DG. Neonatal screening in Vancouver for congenital dislocation of the hip. Can Med Assoc J. 1981;124(8):1003-1008. [pmid: 7260783]. [pmcid: 1705406].
57 Watanabe M, Yanagisawa M, Fukuda S, Takahashi I, Matsumoto M. [Examination, prevention and treatment of congenital dislocation of the hip in the newborn infant—experience over an eighteen-year period]. Nippon Seikeigeka Gakkai Zasshi - J Jap Ortho Assoc. 1986;60(11):1063-1078.
58 Knox EG, Armstrong EH, Lancashire RJ. Effectiveness of screening for congenital dislocation of the hip. J Epidemiol Community Health. 1987;41(4):283-289. [pmid: 3455421]. [pmcid: 1052648].
59 Watanabe M, Yanagisawa M. Late diagnosis of congenital dislocation of the hip in the newborn. Fukushima J Med Sci. 1988;34(2):75-80. [pmid: 3271229].
60 Hazel JR, Beals RK. Diagnosing dislocation of the hip in infancy. West J Med. 1989;151(1):39-41. [pmid: 2763539]. [pmcid: 1026948].
61 Kernohan WG, Nugent GE, Haugh PE, et al. Sensitivity of manual palpation in testing the neonatal hip. Clin Orthop Relat Res. 1993(294):211–215.
62 Clarke NM, Clegg J, Al-Chalabi AN. Ultrasound screening of hips at risk for CDH. Failure to reduce the incidence of late cases. J Bone Joint Surg - British Volume. 1989;71(1):9-12.
63 Sampath JS, Deakin S, Paton RW. Splintage in developmental dysplasia of the hip: how low can we go?. J Pediatr Ortho. 2003;23(3):352-355.
64 Castelein RM, Sauter AJ, de Vlieger M, et al. Natural history of ultrasound hip abnormalities in clinically normal newborns. J Pediatr Ortho. 1992;12(4):423-427.
65 Terjesen T, Holen KJ, Tegnander A. Hip abnormalities detected by ultrasound in clinically normal newborn infants. J Bone Joint Surg - British Volume. 1996;78(4):636-640.
66 Wood MK, Conboy V, Benson MK. Does early treatment by abduction splintage improve the development of dysplastic but stable neonatal hips?. J Pediatr Ortho. 2000;20(3):302-305.
67 Burger BJ, Burger JD, Bos CF, et al. Neonatal screening and staggered early treatment for congenital dislocation or dysplasia of the hip. Lancet. 1990;336(8730):1549-1553. [pmid: 1979375].
68 Marks DS, Clegg J, al-Chalabi AN. Routine ultrasound screening for neonatal hip instability. Can it abolish late-presenting congenital dislocation of the hip?. J Bone Joint Surg - British Volume. 1994;76(4):534-538.
69 Puhan MA, Woolacott N, Kleijnen J, et al. Observational studies on ultrasound screening for developmental dysplasia of the hip in newborns - a systematic review. Ultraschall in der Medizin. 2003;24(6):377-382. [pmid: 14658079].
70 Palmen K. Preluxation of the hip joint. Diagnosis and treatment in the newborn and the diagnosis of congenital dislocation of the hip joint in Sweden during the years 1948-1960. Acta Paediatr. 1961;50(Suppl 129):1-71. [pmid: 13680878].
71 Palmen K. Prevention of congenital dislocation of the hip. The Swedish experience of neonatal treatment of hip joint instability. Acta Ortho Scan. Supplementum. 1984;208:1-107.
72 Graf R. Fundamentals of sonographic diagnosis of infant hip dysplasia. J Pediatr Ortho. 1984;4(6):735-740.
73 Bar-On E, Meyer S, Harari G, et al. Ultrasonography of the hip in developmental hip dysplasia. J Bone Joint Surg - British Volume. 1998;80(2):321-324.
74 Rosendahl K, Aslaksen A, Lie RT, et al. Reliability of ultrasound in the early diagnosis of developmental dysplasia of the hip. Pediatr Radiol. 1995;25(3):219-224. [pmid: 7644309].
75 Dias JJ, Thomas IH, Lamont AC, et al. The reliability of ultrasonographic assessment of neonatal hips. J Bone Joint Surg - British Volume. 1993;75(3):479-482.
76 Jari S, Paton RW, Srinivasan MS. Unilateral limitation of abduction of the hip. A valuable clinical sign for DDH?. J Bone Joint Surg - British Volume. 2002;84(1):104-107.
77 Castelein RM, Korte J. Limited hip abduction in the infant. J Pediatr Ortho. 2001;21(5):668-670.
78 Hansson G, Romanus B, Scheller S. Pitfalls of early diagnosis and treatment of congenital dislocation of the hip joint. Arch Ortho Traumatic Surg. 1988;107(3):129-135.
79 Bialik V, Fishman J, Katzir J, et al. Clinical assessment of hip instability in the newborn by an orthopedic surgeon and a pediatrician. J Pediatr Ortho. 1986;6(6):703-705.
80 Holen KJ, Tegnander A, Terjesen T, et al. Ultrasonography of clinically unstable hips. A prospective study of 143 neonates at birth and early follow-up. Acta Ortho Scan. 1997;68(6):527-532.
81 Lee TW, Skelton RE, Skene C. Routine neonatal examination: effectiveness of trainee paediatrician compared with advanced neonatal nurse practitioner. Arch Dis Child. 2001;85(2):F100-104.
82 Fiddian NJ, Gardiner JC. Screening for congenital dislocation of the hip by physiotherapists. Results of a ten-year study. J Bone Joint Surg - British Volume. 1994;76(3):458-459.
83 Krikler SJ, Dwyer NS. Comparison of results of two approaches to hip screening in infants. J Bone Joint Surg - British Volume. 1992;74(5):701-703.
84 Moore FH. Examining infants' hips—can it do harm?. J Bone Joint Surg - British Volume. 1989;71(1):4-5.
85 Jones DA. Neonatal hip stability and the Barlow test. A study in stillborn babies. J Bone Joint Surg - British Volume. 1991;73(2):216-218.
86 Chow YW, Turner I, Kernohan WG, et al. Measurement of the forces and movements involved in neonatal hip testing. Med Eng Phys. 1994;16(3):181-187. [pmid: 8061903].
87 Andersson JE. Neonatal hip instability: normal values for physiological movement of the femoral head determined by an anterior-dynamic ultrasound method. J Pediatr Ortho. 1995;15(6):736-740.
88 Bone CM, Hsieh GH. The risk of carcinogenesis from radiographs to pediatric orthopaedic patients. J Pediatr Ortho. 2000;20(2):251-254.
89 McHale KA, Corbett D. Parental noncompliance with Pavlik harness treatment of infantile hip problems. J Pediatr Ortho. 1989;9(6):649-652.
90 Bunker JP, Barnes BA, Mosteller F, editors. Costs, risks, and benefits of surgery. New York: Oxford University Press; 1977.
91 Dezateux C, Brown J, Arthur R, et al. Performance, treatment pathways, and effects of alternative policy options for screening for developmental dysplasia of the hip in the United Kingdom. Arch Dis Child. 2003;88(9):753-759. [pmid: 12937091]. [pmcid: 1719641].
92 Aksoy MC, Ozkoc G, Alanay A, et al. Treatment of developmental dysplasia of the hip before walking: results of closed reduction and immobilization in hip spica cast. Turk J Pediatr. 2002;44(2):122-127. [pmid: 12026199].
93 Cashman JP, Round J, Taylor G, et al. The natural history of developmental dysplasia of the hip after early supervised treatment in the Pavlik harness. A prospective, longitudinal follow-up. J Bone Joint Surg - British Volume. 2002;84(3):418-425.
94 Danielsson L. Late-diagnosed DDH: a prospective 11-year follow-up of 71 consecutive patients (75 hips). Acta Ortho Scan. 2000;71(3):232-242.
95 Eidelman M, Katzman A, Freiman S, et al. Treatment of true developmental dysplasia of the hip using Pavlik's method. J Pediatr Ortho. 2003;12(4):253-258.
96 Konigsberg DE, Karol LA, Colby S, et al. Results of medial open reduction of the hip in infants with developmental dislocation of the hip. J Pediatr Ortho. 2003;23(1):1-9.
97 Gregersen HN. Congenital dislocation of the hip. Results of early treatment. Acta Ortho Scan. 1969;40(1):53-61.
98 Malvitz TA, Weinstein SL. Closed reduction for congenital dysplasia of the hip. Functional and radiographic results after an average of thirty years. J Bone Joint Surg - American Volume. 1994;76(12):1777-1792.
99 O'Hara JN, Bernard AA, Dwyer NS. Early results of medial approach open reduction in congenital dislocation of the hip: use before walking age. J Pediatr Ortho. 1988;8(3):288-294.
100 Sosna A, Rejholec M. Ludloff's open reduction of the hip: long-term results. J Pediatr Ortho. 1992;12(5):603-606.
101 Tegnander A, Holen KJ, Anda S, et al. Good results after treatment with the Frejka pillow for hip dysplasia in newborns: a 3-year to 6-year follow-up study. J Pediatr Ortho. 2001;10(3):173-179.
102 Tumer Y, Ward WT, Grudziak J. Medial open reduction in the treatment of developmental dislocation of the hip. J Pediatr Ortho. 1997;17(2):176-180.
103 Yamada N, Maeda S, Fujii G, et al. Closed reduction of developmental dislocation of the hip by prolonged traction. J Bone Joint Surg - British Volume. 2003;85(8):1173-1177.
104 Yoshitaka T, Mitani S, Aoki K, et al. Long-term follow-up of congenital subluxation of the hip. J Pediatr Ortho. 2001;21(4):474-480.
105 Wedge JH, Wasylenko MJ. The natural history of congenital disease of the hip. J Bone Joint Surg - British Volume. 1979;61-B(3):334-338.
106 Wenger DR, Frick SL. Early surgical correction of residual hip dysplasia: the San Diego Children's Hospital approach. Acta Ortho Belgica. 1999;65(3):277-287.
107 Cooperman DR, Wallensten R, Stulberg SD. Post-reduction avascular necrosis in congenital dislocation of the hip. J Bone Joint Surg - American Volume. 1980;62(2):247-258.
108 Schwend RM, Pratt WB, Fultz J. Untreated acetabular dysplasia of the hip in the Navajo. A 34 year case series followup. Clin Orthop Relat Res. 1999(364):108–116.
109 Pratt WB, Freiberger RH, Arnold WD. Untreated congenital hip dysplasia in the Navajo. Clin Orthop Relat Res. 1982(162):69–77.
110 Mladenov K, Dora C, Wicart P, et al. Natural history of hips with borderline acetabular index and acetabular dysplasia in infants. J Pediatr Ortho. 2002;22(5):607-612.
111 Szepesi K, Biro B, Fazekas K, et al. Preliminary results of early open reduction by an anterior approach for congenital dislocation of the hip. J Pediatr Ortho. 1995;4(2):171-178.
112 Castillo R, Sherman FC. Medial adductor open reduction for congenital dislocation of the hip. J Pediatr Ortho. 1990;10(3):335-340.
113 Kruczynski J. Avascular necrosis of the proximal femur in developmental dislocation of the hip. Incidence, risk factors, sequelae and MR imaging for diagnosis and prognosis. Acta Ortho Scan. Supp. 1996;268:1-48.
114 Maxwell SL, Ruiz AL, Lappin KJ, et al. Clinical screening for developmental dysplasia of the hip in Northern Ireland. BMJ. 2002;324(7344):1031-1033. [pmid: 11976249]. [pmcid: 1122960].
115 Bicimoglu A, Agus H, Omeroglu H, et al. Six years of experience with a new surgical algorithm in developmental dysplasia of the hip in children under 18 months of age. J Pediatr Ortho. 2003;23(6):693-698.
116 Takahashi I. Functional treatment of congenital dislocation of the hip using Pavlik harness (Riemenbugel). Nippon Seikeigeka Gakkai Zasshi - J Jap Ortho Assoc. 1985;59(11):973-984.
117 Severin E. Contribution to the knowledge of congenital dislocation of the hip: late results of closed reduction and arthrographic studies of recent cases. Acta Chir Scand. 1941;84(Supplementum 63):1-142.
118 Smith WS, Badgley CE, Orwig JB, et al. Correlation of postreduction roentgenograms and thirty-one-year follow-up in congenital dislocation of the hip. J Bone Joint Surg - American Volume. 1968;50(6):1081-1098.
119 Ali AM, Angliss R, Fujii G, et al. Reliability of the Severin classification in the assessment of developmental dysplasia of the hip. J Pediatr Ortho. 2001;10(4):293-297.
120 Ward WT, Vogt M, Grudziak JS, et al. Severin classification system for evaluation of the results of operative treatment of congenital dislocation of the hip. A study of intraobserver and interobserver reliability. J Bone Joint Surg - American Volume. 1997;79(5):656-663.
121 Brougham DI, Broughton NS, Cole WG, et al. Avascular necrosis following closed reduction of congenital dislocation of the hip. Review of influencing factors and long-term follow-up. J Bone Joint Surg - British Volume. 1990;72(4):557-562.
122 Buchanan JR, Greer RB 3rd, Cotler JM. Management strategy for prevention of avascular necrosis during treatment of congenital dislocation of the hip. J Bone Joint Surg - American Volume. 1981;63(1):140-146.
123 Grill F, Bensahel H, Canadell J, et al. The Pavlik harness in the treatment of congenital dislocating hip: report on a multicenter study of the European Paediatric Orthopaedic Society. J Pediatr Ortho. 1988;8(1):1-8.
124 Lennox IA, McLauchlan J, Murali R. Failures of screening and management of congenital dislocation of the hip. J Bone Joint Surg - British Volume. 1993;75(1):72-75.
125 Pool RD, Foster BK, Paterson DC. Avascular necrosis in congenital hip dislocation. The significance of splintage. J Bone Joint Surg - British Volume. 1986;68(3):427-430.
126 Powell EN, Gerratana FJ, Gage JR. Open reduction for congenital hip dislocation: the risk of avascular necrosis with three different approaches. J Pediatr Ortho. 1986;6(2):127-132.
127 Suzuki S, Seto Y, Futami T, et al. Preliminary traction and the use of under-thigh pillows to prevent avascular necrosis of the femoral head in Pavlik harness treatment of developmental dysplasia of the hip. J Orthop Sci. 2000;5(6):540-545. [pmid: 11180915].
128 Thomas IH, Dunin AJ, Cole WG, et al. Avascular necrosis after open reduction for congenital dislocation of the hip: analysis of causative factors and natural history. J Pediatr Ortho. 1989;9(5):525-531.
129 Weiner DS. Avascular necrosis as a treatment complication in congenital dislocation of the hip in children under one year of age. Isr J Med Sci. 1980;16(4):301-306. [pmid: 7390780].
130 Standen PJ. The long-term psychological adjustment of children treated for congenital dislocation of the hip. Psychol Med. 1983;13(4):847-854. [pmid: 6665101].
131 Brown J, Dezateux C, Karnon J, et al. Efficiency of alternative policy options for screening for developmental dysplasia of the hip in the United Kingdom. Arch Dis Child. 2003;88(9):760-766. [pmid: 12937092]. [pmcid: 1719653].
132 Bralic I, Vrdoljak J, Kovacic L. Ultrasound screening of the neonatal hip: cost-benefit analysis. Croat Med J. 2001;42(2):171-174. [pmid: 11259740].
133 Clegg J, Bache CE, Raut VV. Financial justification for routine ultrasound screening of the neonatal hip. J Bone Joint Surg - British Volume. 1999;81(5):852-857.
134 Faure C, Schmit P, Salvat D. Cost-benefit evaluation of systematic radiological diagnosis of congenital dislocated hip. Pediatr Radiol. 1984;14(6):407-412. [pmid: 6438600].
135 Rosendahl K, Markestad T, Lie RT, et al. Cost-effectiveness of alternative screening strategies for developmental dysplasia of the hip. Arch PediatrAdolesc Med. 1995;149(6):643-648.
136 Geitung JT, Rosendahl K, Sudmann E. Cost-effectiveness of ultrasonographic screening for congenital hip dysplasia in new-borns. Skeletal Radiol. 1996;25(3):251-254. [pmid: 8741062].