# Acknowledgements

This evidence synthesis was funded by the Agency for Healthcare Research & Quality (AHRQ) for the U.S. Preventive Services Task Force (USPSTF). The investigators thank, Ronald Turker, MD, for serving as a consultant, the USPSTF liaisons, Carol Loveland-Cherry, PhD, RN, Leon Gordis, MD, MPH, DrPH, Virginia Moyer, MD, MPH, and Barbara Yawn, MD, MSc, the AHRQ Medical Officer, Iris Mabry, MD, expert reviewers listed in the Appendix of this report for commenting on draft versions, Andrew Hamilton, MLS, MS for conducting the literature searches, and Miranda Walker for assisting with the manuscript.

## Requests for Reprints

Reprints are available from the AHRQ Web site at www.ahrq.gov (click on Preventive Services).