# Discussion

## Conclusions and Limitations of the Literature

As a condition that can result in impaired functional outcomes for children and adults, DDH merits the attention of primary care clinicians. However, as shown in Table 7, there is no direct evidence that screening improves functional outcomes, and the evidence for several links in the analytic framework is weak.

Table 7 Summary of Evidence

Arrow | Key Question | Level and Type of Evidence
1 | Does screening for DDH lead to reduced need for surgery or improved functional outcomes? | Poor: no controlled studies have compared screening with no screening to determine whether there is an impact on functional outcomes; there is conflicting evidence from ecologic studies that screening reduces rates of surgery
2 | Can infants at high risk for DDH be identified, and does this group warrant a different approach to screening than children at average risk? | Fair: in case-control and cohort studies, family history, breech presentation, and clinical instability are consistently associated with a high risk of DDH, but most infants with DDH do not have risk factors
| | poor: practice-based, prospective studies on on the performance of risk assessment instruments are lacking
3 | Does screening for DDH lead to early identification of children with DDH? | See 3a, 3b, 3c below
3a | What is the sensitivity, specificity, and predictive value of screening exams? (e.g., Barlow/Ortolani, other exam findings, ultrasonography, and radiographs) | Poor: ascertainment of test characteristics is unreliable, because definitions of a positive test vary, and most studies did not use an independent standard to determine disease status; low risk/ screen negative patients rare followed with intensity of high risk/screen positive patients; high rates of spontaneous resolution have been reported
| | fair: most hip dysplasia identified by early ultrasound will resolve spontaneously in first weeks of life
3b | How does the age of the child affect screening parameters? | Fair: limited hip abduction becomes a more sensitive sign of DDH over the first several months of life
3c | How does the educational level and training of the screener impact screening? | Fair: experience with the clinical examination of the hip in infants predicts screen positive rates and accuracy of exam, but few head-to-head comparisons without biases have been conducted; consistent but limited amount of evidence that well-trained non-physicians can interpret clinical examination findings as well as pediatricians and better than physicians-in-training
4 | What are the adverse effects of screening? | Poor: in theory, forceful exam of already-lax newborn hips might cause injury or dislocation, but there is limited and conflicting evidence regarding this hypothesis
5 | Does early diagnosis of DDH lead to early intervention, and does early intervention lead to improved functional outcomes? Is the likelihood of surgical intervention reduced in children diagnosed at an earlier age? | Fair: early diagnosis leads to early intervention; evidence of the effectiveness of intervention is inconclusive, due to 1) high rate of spontaneous resolution, 2) absence of comparative studies of intervention vs. no intervention, 3) variation in surgical indications and protocols; few studies examine functional outcomes in a valid and reliable fashion
| | fair-poor: evidence is limited and mixed on the effect of earlier diagnosis on likelihood of surgery
6 | What are the adverse effects of early diagnosis and/or surgical and non-surgical interventions? | Fair: all nonsurgical and surgical interventions are associated with a risk of avascular necrosis; many nonsurgical interventions are in use, but data are insufficient to determine whether there are differences among them; this is also true of surgical interventions

The definition of DDH is variable, including dislocated, dislocatable, subluxable, and dysplastic hips. The benefits of early intervention are based on expert opinion along with fair evidence that later diagnosis results in worse outcomes and greater need for surgical intervention. Using indirect comparisons, some studies suggest that earlier diagnosis is associated with better outcomes, but these findings could be the result of lead-time bias, that is, the identification of DDH in a group of younger patients, in whom a higher rate of spontaneous resolution may lead to better outcomes, versus the effect of earlier intervention. The outcomes of screened infants have not been compared to those of unscreened infants in an experimental or observational study.

Despite a paucity of direct evidence supporting its value in improving outcomes, universal screening for DDH is a well-established approach to the disorder. However, the approach to screening varies significantly. In addition to physical examination with the provocative tests of Barlow and Ortolani and evaluation of range of motion emphasizing abduction of the hip, static and dynamic ultrasound are employed to identify anatomic abnormalities and stability of the hip, respectively.

Some have recommended risk stratification to inform selective use of ultrasound, with females in breech positioning at delivery found to have the highest rate of clinical hip instability (84/1000) and subsequent rate of treatment (20/1000). Other health systems have elected to employ universal ultrasound screening in an effort to reduce the incidence of late diagnosis of DDH (variably defined in the literature as diagnosis beyond 1, 3, 6, or 12 months of age). The use of ultrasound to further evaluate hips found to be unstable on clinical exam may reduce the rate of unnecessary treatment. However, the reliability of the approach to DDH classification by ultrasound is questionable. Theoretical harms from screening include examiner induced hip pathology with vigorous provocative testing, elevated risk of certain cancers from increased radiation exposure from follow-up radiographic tests, and parental psychosocial stress from the diagnosis and therapy. None of these has been quantified in patients/families in clinical studies published to date beyond anecdotes.

It is known that a significant number of hips with positive screening tests, both by physical examination and by ultrasound, will normalize over time without intervention. This is particularly true of ultrasound in hips that are stable on clinical exam of the neonate: more than 90% of abnormal ultrasound findings in this situation have been shown to normalize spontaneously. While limited fair quality evidence exists to support the value of initiating treatment within the first 6 months of life, there is little to suggest that immediate treatment in the newborn period is associated with improved outcomes or a reduced need for subsequent surgery. However, no study has examined the effect of timing of treatment initiation, controlling for the degree of instability (dysplastic, subluxated, dislocatable, dislocated).

First-line intervention includes abduction bracing of the hips, which attempts to induce passive alignment of the hip. Several devices are used for abduction, with a wide range of institutional protocols. Failure of abduction therapy, or the occasional case of dislocated and clinically irreducible hips at presentation, leads to surgical intervention, including one or more of the following: closed reduction under general anesthesia, open reduction, and femoral and/or acetabular osteotomies. The indications and protocols for surgery vary widely, as do the pre- and post-operative approaches to management, which include traction, hip spica casting, and/or various forms of abduction bracing for extended periods.

Estimates of the effectiveness of therapy are confounded by spontaneous resolution of hip dysplasia, which has only rarely been assessed and never in a prospective or comparative fashion. The impact of interventions on functional outcomes is rarely addressed in the literature, and when addressed is of poor quality due to a lack of standardization within studies, and the absence of validated functional outcome measures across studies.

The most significant and common adverse effect of both nonsurgical and surgical intervention for hip dysplasia is avascular necrosis of the femoral head, which can lead to growth arrest and eventual destruction of the hip joint. Assessment of the cost effectiveness of screening for DDH requires more conclusive information about effectiveness. Studies including cost data on various screening programs have been conducted outside the U.S. and may not be generalizable to health care delivery in this country.

## Future Research

While the body of literature on screening and intervention for DDH has significant flaws, several recent studies provide valuable information on the screening evaluation of DDH. A more complete understanding of the natural history of spontaneous resolution of hip instability and dysplasia is needed to develop an evidence-based strategy for conducting screening and implementing therapy at the optimal time. Given the infrequent nature of DDH, multicenter studies of interventions that measure functional outcomes in a standardized fashion are needed. Studies designed to assess whether any clearly defined, reliable radiological markers predict functional outcomes would be a valuable step. Even more valuable would be patient-centered research that seeks to understand patient and family preferences as they relate to the process of care and short and long-term outcomes of DDH.