# Methods

## Literature Search Strategy

The most recent systematic reviews of screening for DDH, by the AAP and the CTFPHC, targeted many of the same questions as this report. We analyzed their reviews to focus the search strategy and eligibility criteria for our review. When questions had substantial overlap, we reviewed all studies identified in these reviews and searched the literature for studies published subsequently (after 1996 for the AAP review and 2000 for the CTFPHC review).

For most key questions, relevant studies were identified from multiple searches of MEDLINE (1966 to January 2005) and the Cochrane Library databases through June of 2004. Search strategies are described in Appendix 2. Additional articles were obtained by reviewing reference lists of other pertinent studies, reviews, editorials, and websites, and by consulting experts. We modified this strategy after reviewing the two previous systematic reviews (see Results section, subsection Previous Systematic Reviews). Specifically, for assessments of screening modalities in Key Question 3, we examined the literature beginning in 1996, the year in which the AAP review concluded.

## Inclusion/Exclusion Criteria

Investigators reviewed all abstracts identified in the searches and the previous systematic reviews and determined eligibility by applying inclusion and exclusion criteria specific to key questions (Appendix 3). Full-text papers of included abstracts were then reviewed for relevance. Eligible studies had English-language abstracts, were applicable to U.S. clinical practice, and provided primary data relevant to key questions. Initial screening had to be done in children less than 6 months of age, and screening studies needed to be prospective, primary care based or population based in design. Studies of risk factors also had to be primary care based or population based. Intervention and outcomes studies had to report results of children diagnosed before 6 months of age, and interventions had to be employed earlier than 1 year of age on average. For intervention studies, we were particularly interested in functional outcomes, including: gait, pain, physical functioning, activity level, peer relations, family relations, school and occupational performance. For noninvasive interventions, another potential benefit is a reduced need for surgery later in childhood. Therefore, intervention studies were eligible if they reported one of these functional outcomes and/or a subsequent need for surgery. We excluded studies that reported only radiological reports of anatomic structural relationships and development, which have not been shown to be valid predictors of functional outcomes. For avascular necrosis (AVN), the predominant harm from interventions, studies needed to report the rate of this complication in the treated patient population, meet age-based inclusion criteria, have at least 1 year of follow-up, and not experience excessive (>50%) loss to follow-up.

We used a “best evidence” approach ^18^ ; that is, for each key question, we included studies with weaker designs only if better-designed studies were not available. Case reports, series with 5 or fewer subjects, editorials, letters, nonsystematic review articles, and commentaries were also excluded from the evidence review.

## Data Extraction and Synthesis

Data were extracted from each study, entered into evidence tables, and summarized by descriptive and statistical methods as appropriate. We rated the internal validity of each included study using criteria specific to different study designs developed by the USPSTF (Appendix 4). ^19^ The USPSTF quality criteria can be used to appraise controlled trials, observational, comparative studies such as cohort and case-control studies, and studies evaluating the performance of diagnostic tests. Studies with flaws deemed to invalidate the results were labeled as poor in quality, and were not included in the evidence report.

Most studies of DDH are observational, uncontrolled or poorly controlled, and have serious flaws in design (grade of II-3 or III according to the original USPSTF classification.) There are no USPSTF criteria to rate such studies good, fair, or poor, but we highlight their limitations. To assess the quality of these studies, we considered the following: study design, clarity of diagnostic standards, comparability of subjects, variation in screening approach and/or intervention protocol, duration of follow-up, loss to follow-up, efforts to control for confounding and minimize bias, masking of outcome assessors, and validity and standardization of outcomes measured. ^20^

## Size of Literature Reviewed

Investigators reviewed 1,145 abstracts of English-language articles identified by the searches, excluding 679 citations on first review (Appendix 5). A total of 466 full-text articles were retrieved and reviewed; 416 were from the electronic searches and 50 were from reference lists or experts' suggestions (expert reviewers listed in Appendix 6). Thirteen papers about risk factors; 59 about screening, including 3 controlled trials; 5 about harms of screening; 47 about interventions and harms of interventions, including no controlled trials; and 8 about cost met the inclusion criteria. Review of an additional 544 abstracts of non-English language articles did not identify any additional controlled trials.

Appendix 5. Search and Selection of the Literature