# Introduction

Developmental dislocation of the hip can lead to premature degenerative joint disease, impaired walking, and pain. Surgery is often necessary once these complications have occurred. Hip instability can be treated nonsurgically if it is detected early. Neonatal screening, which has been practiced for almost four decades, is intended to reduce the need for surgery, prevent degenerative joint disease, pain, and mobility limitations.

This evidence synthesis focuses on screening and intervention for developmental dysplasia of the hip (DDH) in physiologically normal infants from birth through 6 months. The review was conducted for the U.S. Preventive Services Task Force (USPSTF), which had no previous recommendations for this condition. Two systematic reviews of DDH have been published, one by the Canadian Task Force on Preventive Health Care (CTFPHC) ^1^ and another by the American Academy of Pediatrics (AAP). ^2,^ ^3^ This evidence synthesis will summarize this previous work with a focus on how methods and conclusions agree and differ, and incorporates published studies since these reviews were completed.

## Burden of Condition

DDH represents a spectrum of anatomical abnormalities in which the femoral head and the acetabulum are in improper alignment and/or grow abnormally. The precise definition of DDH is controversial. ^2,^ ^4^ The spectrum includes hips that are dysplastic, subluxated, dislocatable and dislocated. Clinical instability of the hip is the traditional hallmark of the disorder. In an unstable hip, the femoral head and acetabulum may not have a normal tight, concentric anatomic relationship, which can lead to abnormal growth of the hip joint and may result in permanent disability.

Nonspecific instability in the hip is a common finding in newborns. ^5^ This is particularly true in females, in whom the maternal hormone relaxin may contribute to ligamentous laxity. More than 80% of clinically unstable hips noted at birth have been shown to resolve spontaneously. ^6^ However, due to the potential for subsequent impairment and the widespread belief that earlier treatment leads to improved outcomes, screening newborns for DDH has become commonplace.

Estimates of the incidence of DDH in infants vary between 1.5 and 20 per 1000 births. ^1^ The incidence of DDH in infants is influenced by a number of factors, including diagnostic criteria, gender, genetic and racial factors, and age of the population in question. ^3^ The reported incidence has increased dramatically since the advent of clinical and sonographic screening, suggesting possible overdiagnosis. ^4^ Risk factors for the development of DDH include gender, family history of DDH, breech intrauterine positioning, and additional in utero postural deformities. ^7^ – ^9^ However, the majority of cases of DDH have no identifiable risk factors. ^10^

The most common methods of screening for DDH involve the physical examination of the hips and lower extremities. Provocative testing includes the Barlow and Ortolani procedures, which involve adduction of the flexed hip with gentle posterior force, and abduction of the flexed hip with gentle anterior force, respectively. The Barlow test attempts to identify a dislocatable hip, ^6,^ ^11^ while the Ortolani exam attempts to relocate a dislocated hip. ^12^ Additional findings reported on physical examination in infants include asymmetry of gluteal and thigh skin folds, discrepant leg lengths, and diminished range of motion (particularly abduction) in an affected hip. ^3^ Due to variations in technique, the provocative Barlow and Ortolani tests have been shown to have a high degree of operator dependence. ^13^ In addition, confusion about the identification of a “click” versus a “clunk” on these tests, and the significance of each of these findings, can lead to disparate conclusions between examiners.

Ultrasonography and radiography are also used to screen for DDH. X-ray is less accurate in the first 3–4 months of life, when the bones of the hip are not completely ossified. The use of ultrasonography and/or radiography in screening has been controversial, particularly due to reports of high false positive rates leading to unnecessary and potentially harmful follow-up and intervention. ^14^ Despite the controversy, ultrasound has been widely incorporated into DDH screening programs in many developed countries. ^15,^ ^16^

## Healthcare Interventions

Intervention for DDH includes both nonsurgical and surgical options. A variety of abduction devices are used to treat DDH nonsurgically, with the Pavlik method among the most common. These devices place the legs and hips in an abducted and flexed position in an effort to promote stabilization of the hip joint. The duration of treatment varies from center to center. Complications of nonsurgical therapy are not trivial, with avascular necrosis of the femoral head among the most serious. ^1^

Surgical intervention is necessary when DDH is severe, when it is diagnosed late, or after an unsuccessful trial of nonsurgical methods. ^17^ Many surgical procedures are used to treat DDH (Appendix 1). Most involve reduction of the femoral head into the acetabulum, with or without additional procedures on the adductor tendons, the femur, or the acetabulum. Preoperative management often includes a period of traction, and postoperative management typically includes a period of fixed positioning in a spica cast. The duration and specific approach to pre- and post-operative management are highly variable. Surgical intervention places the hip at risk of avascular necrosis, in addition to standard operative risks including general anesthesia, intraoperative complications, and post-operative wound infections.

For the purposes of this review, all nonsurgical abduction therapy was considered as a whole, distinct from all surgical procedures which were also considered collectively. Since closed manual reduction of the hip typically requires general anesthesia, it was considered along with other surgical procedures.

## Prior Recommendations

In 2000, the AAP used a combination of expert panel, decision modeling, and evidence synthesis to develop DDH screening guidelines. The AAP recommended universal screening of newborns by serial physical examination, with 2 week follow-up examination for equivocal findings and referral to an orthopedist for positive Barlow and Ortolani tests. ^2,^ ^3^ They also emphasized the importance of considering risk factors in the approach to screening, recommending ultrasound in females born breech, and recognizing ultrasound of all infants born breech as a reasonable approach. However, they did not recommend universal ultrasound screening. The AAP report did not examine the effectiveness of therapy (Table 1).

Table 1 Previous Recommendations by the American Academy of Pediatrics and the Canadian Task Force for DDH for Newborns and Infants*

Screening Interventions | Summary Findings | Level of Evidence** | Quality of Evidence | Recommendations
Serial clinical examination of the hips by a trained clinician during the periodic health examination in all infants (until walking independently) | Decreases the operative rate from 1–2 per 1000 infants to 0.2–0.7 per 1000 | III | CTF: “Fair” | BOTH RECOMMEND
| | | AAP: “Good” | CTF: (B)
| | | | AAP: “Strong”
Ultrasound screening (static or dynamic method) in all infants | Increases splint rate without decreasing late surgery rate | II-1, III | Both: “Fair” | BOTH RECOMMEND AGAINST
| | | | CTF: (D)
| | | | AAP: “Strong”
Ultrasound screening in high-risk infants | Does not affect many infants and does not reduce the operative rate | II-1, III | CTF: “Fair” | CTF RECOMMENDS AGAINST (D)
| | | AAP: “Strong” | AAP RECOMMENDS “Strong”
Routine radiographic screening at ages 3 to 5 months | Test is unreliable | III | CTF: “Fair” | CTF RECOMMENDS AGAINST (D)
Ultrasound or radiograph if positive clinical exam | Does not influence management | | AAP: “Poor” | AAP RECOMMENDS AGAINST “Strong”
[underlined: Positive screen]: refer to orthopedist | | | AAP: “Good” | AAP RECOMMENDS “Strong”
[underlined: Equivocal screen]: follow-up in 2 weeks
[underlined: Negative screen]: follow-up in 2 months
[underlined: Suspicious] physical, not positive: refer to orthopedist or obtain ultrasound 3–4 weeks | | | None | AAP was “Mixed”
Treatment Interventions
Triple diapering | Effectiveness unknown, may delay definitive therapy, though may aid in ensuring follow-up | | AAP: “Poor” | AAP RECOMMENDS AGAINST “Strong”
Abduction therapy | Effectiveness unknown. Causes avascular necrosis of the hip (in 1%–4% of treated infants) | III | | CTF DOES NOT RECOMMEND (C)
Observation before intervening | DDH resolves spontaneously in many cases | I | CTF: “Good” | CTF RECOMMENDS (A)

“I”, controlled trial with randomization; “II-1”, controlled trial without randomization; “III”, expert opinion; AAP - American Academy of Pediatrics; CTF - Canadian Task Force

* For more details on quality and recommendation coding, please see Patel (2001) & Lehmenn (2000).

In 2001, the CTFPHC also recommended universal screening via serial physical examination of the hips until the patient is walking. ^1^ They recommended against the use of ultrasound or radiography in a selective approach to screening, in contrast to the AAP report, and concurred with the AAP report in opposing universal ultrasound screening. The CTFPHC examined the literature on abduction therapy for DDH, and concluded that there was insufficient evidence to evaluate the effectiveness of this intervention (Table 1).

## Scope of Evidence Synthesis

The analytic framework (Figure 1) and key questions (Figure 2) guiding the literature review were developed in consultation with liaisons from the USPSTF. We focused on screening in infants from birth through 6 months of age. We excluded so-called teratological DDH, that occurring in children with neuromuscular disorders or other congenital malformations. We included literature on the effects of both nonsurgical (abduction braces) and surgical interventions on functional outcomes, including gait, pain, physical functioning, activity level, peer relations, family relations, school and occupational performance.

Figure 1. Analytic Framework

Figure 2. Key Questions

The key questions examine critical links in the logic underlying screening. To be effective, screening must identify cases of DDH earlier than they would be identified in the usual course of care (Key Questions 2, 3). In addition, early identification must lead to earlier treatment, and earlier treatment must lead to better functional outcomes than late treatment (KQ5). Finally, the benefits of early identification and treatment must outweigh the harms of screening and of the treatments themselves (KQ4, 6).