# Appendix 7. Literature Concordance with the Canadian Task Force on Preventive Health Care Review

CTFPHC Force Citation | Inclusion/ Exclusion | Reason for Exclusion
Andersson, 1995 | Include
Barlow, 1962 | Include
Bialik, 1999 | Include
Boere-Boonekamp, 1998 | Include
Burger, 1990 | Include
Clarke, 1989 | Include
Dias, 1993 | Include
Dunn, 1985 | Include
Gardiner, 1990 | Include
Godward, 1998 | Include
Graf, 1984 | Include
Krikler, 1992 | Include
Lennox, 1993 | Include
Macnicol, 1990 | Include
Marks, 1994 | Include
Place, 1978 | Include
Rosendahl, 1995 | Include
Rosendahl, 1994 | Include
Tonnis, 1990 | Include
Tredwell, 1981 | Include
Wedge, 1979 | Include
Berman, 1986 | Exclude | Pre-1996 study of screening modalities
Castelein, 1988 | Exclude | Pre-1996 study of screening modalities
Catterall, 1994 | Exclude | Expert opinion
Cheng, 1994 | Exclude | Pre-1996, no comparison of screening modalities
Clarke, 1992 | Exclude | Editorial/expert opinion
Davids, 1995 | Exclude | Non-primary care based
Dodenhoff, 1996 | Exclude | Letter
Donaldson, 1994 | Exclude | Commentary
Fulton, 1984 | Exclude | Economic Analysis based on data no longer relevant to management
Garvey, 1992 | Exclude | Pre-1996 study of screening modalities
Gerscovich, 1997 | Exclude | Nonsystematic review
Hansson, 1997 | Exclude | Commentary
Harcke, 1993 | Exclude | Commentary
Hernandez, 1995 | Exclude | Editorial/expert opinion
Hernandez, 1994 | Exclude | Poor quality: high risk of bias not accounted for in analysis
Holen, 1994 | Exclude | Pre-1996 screening modalities study; all data from study captured and included in Holen 2002
Jomha, 1995 | Exclude | Pre-1996, retrospective, nonconsecutive sample in a study of screening modality
Jones, 1989 | Exclude | Pre-1996, no comparison of screening modalities
Jones, 1990 | Exclude | Pre-1996 study of screening modalities
Langkamer, 1991 | Exclude | Case report
Lehmann, 1981 | Exclude | Pre-1996, retrospective, no comparison between screening modalities
Mooney, 1995 | Exclude | Nonsystematic review
Poul, 1992 | Exclude | Pre-1996, no comparison between screening modalities
Poul, 1998 | Exclude | No comparison between screening modalities
Rembold, 1998 | Exclude | Not specific to DDH
Rosendahl, 1992 | Exclude | Pre-1996 study of screening modalities
Secretaries of State for Social Services/ Wales | Exclude | Nonsystematic review; Standing Medical Advisory Committee
Walker, 1977 | Exclude | Poor quality: design with high risk of ascertainment bias; reports relative lack of disability but does not quantify
Wolfe, 1990 | Exclude | Not specific to DDH
Von Rosen, 1956 | Exclude | No functional outcomes
Weinstein, 1987 | Exclude | Nonsystematic review
Zieger, 1986a | Exclude | Nonsystematic review, out of scope
Zieger, 1986b | Exclude | Not specific to DDH, no age of patients given
Zieger, 1987 | Exclude | Pre-1996 screening, no age of patients given