# Appendix 6. Expert Reviewers

Content Experts

- Viktor Bialik, MD, PhD
- Director, Pediatric Orthopedics Unit
- Rambam Medical Center/ Technion-Israel Institute of Haifa, Israel

- Michael Goldberg, MD
- Chairman, Department of Orthopedics
- Tufts University School of Medicine

- Harold Lehmann, MD, PhD
- Associate Professor, Department of Pediatrics and Health Sciences Informatics
- Johns Hopkins Medical Institutions

- Hema Patel, MD
- Montreal Children's Hospital /McGill University Health Centre
- Montreal, Quebec

- Ronald Turker, MD
- Head, Pediatric Orthopaedics
- Oregon Health and Science University

Professional Societies or Organizations

- Jon R Davids, MD
- Assistant Chief, Shriners Hospitals for Children and Director, Motion Analysis Lab
- Orthopaedic Surgery Faculty
- On behalf of the Pediatric Orthopaedic Society of North America (POSNA)

- Michael Vitale, MD, MPH
- Assistant Professor, Division of Pediatric Orthopaedic Surgery and Assistant Professor of Orthopaedic Surgery / Columbia University
- On behalf of the American Academy of Orthopaedic Surgeons/American Association of Orthopaedic Surgeons (AAOS), the Pediatric Orthopaedic Society of North America (POSNA), and the American Academy of Pediatrics (AAP)

US Preventive Service Task Force Leads

Carol Loveland-Cherry, PhD, RN, FAAN

Virginia Moyer, MD, MPH

Barbara Yawn, MD, MSc, FAAFP

Keith R Gabriel, MD

Federal Agencies

- Iris Mabry, MD, MPH
- Agency for Healthcare, Research, and Quality

- Tyl Hewitt, PhD
- NICHD, NIH

- James Panagis, MD, MPH
- National Institute of Arthritis and Musculoskeletal and Skin Diseases, NIH

- Dennis Wen, MD
- Department of Family and Community Medicine
- University of Missouri