# Appendix 3. Abstract Inclusion/Exclusion Criteria

Developmental Dysplasia of the Hip

Include | Randomized control trial
| Comparative study (cohort, case-control, or observational)
| Systematic reviews, standards, or guidelines
| Relevant for risk
| Relevant for screening
| Relevant for harms
| Relevant for intervention
| Relevant for harms of intervention
| Relevant for cost
| Relevant for background or epidemiology
| Relevant for methodology
| US or non-US (if applicable) population
Exclude | Letters, editorials, nonsystematic reviews, commentaries
| Case reports
| Less than 5 cases
| Screened age beyond six months
| Intervention age (mean) beyond one year
| Children with teratological DDH (neuromuscular disorders, multiple congenital anomalies)
| Salvage procedures
| Information not relevant or outside scope
| Poor quality study
| Non-English language
| Non-human