# Appendix 2. Search Strategies

Database: MEDLINE (1966 to January 2005)

Screening and Adverse Effects of Screening

Screening

1 exp Hip Dislocation, Congenital/pa, di, ra, ri, us
2 exp “Diagnostic Techniques and Procedures”/
3 exp Hip Dislocation, Congenital/
4 2 and 3
5 1 or 4
6 exp “Sensitivity and Specificity”/
7 5 and 6
8 limit 7 to (English language and all child <0 to 18 years>)

Cost analysis

9 exp “Costs and Cost Analysis”/
10 5 and 9
11 exp Hip Dislocation, Congenital/ec
12 10 or 11
13 limit 12 to (English language and all child <0 to 18 years>)

Age of child and frequency of screening

14 exp Age Factors/
15 5 and 14
16 exp time factors/
17 5 and 16
18 15 or 17
19 limit 18 to (English language and all child <0 to 18 years>)

Risk of DDH

20 exp RISK/
21 5 and 20
22 limit 21 to (English language and all child <0 to 18 years>)

Diagnostic errors of screening

23 exp Diagnostic Errors/
24 5 and 23
25 limit 24 to (English language and all child <0 to 18

Educational level and training of screener

26 family physician$.mp. or exp Physicians, Family/
27 primary care.mp. or exp Primary Health Care/exp NURSES/ or exp NURSE'S ROLE/ or exp
28 NURSES' AIDES/ or exp nursing care/
29 exp Pediatrics/ or pediatrician$.mp.
30 exp physician assistants/ or physican assistant$.mp.
31 26 or 27 or 28 or 29 or 30
32 5 and 31
33 limit 32 to (English language and all child <0 to 18 years>)

Adverse effects of screening

34 (adverse$ adj5 effect$).mp.
35 5 and 34
36 exp “Wounds and Injuries”/et
37 5 and 36
38 35 or 37
39 limit 38 to (English language and all child <0 to 18 years>)

Types of studies

40 Comparative Study/
41 exp Evaluation Studies/
42 exp Epidemiologic Studies/
43 40 or 41 or 42
44 5 and 43
45 limit 44 to (English language and all child <0 to 18

Age limit

46 limit 44 to (English language and all infant <birth to 23 months>)

Barlow

1 barlow.tw.
2 ortolani.mp.
3 1 or 2
4 (hip or dysplas$ or cdh or congenit$).mp.
5 3 and 4
6 limit 5 to human
7 limit 6 to english language
8 limit 6 to abstracts
9 7 or 8
10 from 9 keep 1–64

Outcomes, Interventions, and Adverse Effects of Interventions

Outcomes

1 exp Hip Dislocation, Congenital/nu, pc, dt, rh, su, th
2 exp “Outcome and Process Assessment (Health Care)”/
3 1 and 2
4 limit 3 to (English language and all child <0 to 18 years>)

Age of child

5 exp Age Factors/
6 1 and 5
7 limit 6 to (English language and all child <0 to 18 years>)

Types of studies

8 Comparative Study/
9 exp Evaluation Studies/
10 exp Epidemiologic Studies/
11 8 or 9 or 10
12 1 and 11
13 limit 12 to (English language and all child <0 to 18 years>)

Surgical vs. non-surgical

14 exp Hip Dislocation, Congenital/nu, pc, dt, rh, th
15 2 and 14
16 limit 15 to (English language and all child <0 to 18 years>)
17 exp Hip Dislocation, Congenital/su
18 2 and 17
19 limit 17 to (English language and all child <0 to 18 years>)

Time factors, diagnoses, and outcomes

20 exp Time Factors/
21 exp Hip Dislocation, Congenital/pa, di, ra, ri, us
22 exp Hip Dislocation, Congenital/
23 exp diagnosis/
24 22 and 23
25 21 or 24
26 17 and (5 or 20) and 25
27 limit 26 to (English language and all child <0 to 18 years>)

Adverse effects of interventions

28 (adverse$ adj5 effect$).mp.
29 1 and 28
30 exp “Wounds and Injuries”/et
31 1 and 30
32 29 or 31
33 limit 32 to (English language and all child <0 to 18 years>)

Pavlik

1 pavlik.tw.
2 (hip or dysplas$ or cdh or congenit$).mp.
3 1 and 2
4 limit 3 to human
5 limit 4 to english language
6 limit 4 to abstracts
7 5 or 6
8 from 7 keep 1–129

Classification and Differential Diagnosis of DDH

1 exp Hip Dislocation, Congenital/cl [Classification]
2 exp Hip Dislocation, Congenital/
3 diagnosis, differential/
4 2 and 3
5 1 or 4
6 limit 5 to (English language and all child <0 to 18 years>)

Cochrane Databases

Searched the keyword “hip dysplasia” through June 2004 in the following databases:

- Cochrane Central Register of Controlled Trials
- Cochrane Database of Systematic Reviews
- Cochrane DSR, ACP Journal Club, and DARE

Automatic Updates

Weekly updates for key question's 2,3,4 combined

Weekly updates for key question's 2,3,4,5,6 combined