# Appendix 1. Devices and Procedures

Nonsurgical Abduction Devices

Abduction brace

Becker device

Craig splint

Divaricator splint

Frejka pillow

Immobilization in hip spica

Knee splint harness

Pavlik harness

Traction

von Rosen

Surgical Procedures

Anterolateral open reduction

Closed reduction

Dega osteotomy

Derotation osteotomy

Femoral osteotomy

Fergusen medial approach

Harris hip-rating system

Kalamchi modification of salter osteotomy

Ludloff's medial approach

Medial adductor open reduction

Medial open reduction

Open reduction

Osteotomy of the pelvis

Pemberton osteotomy

Pemberton acetabuloplasty

Salter Innominate osteotomy

Varus derotational osteotomy

Salvage Procedures

Chairi pelvic osteotomy

Colonna's operation

Rotational acetabular osteotomy

Shelf operation

Total hip arthroplasty

Triple innominate osteotomy