# Appendixes

Appendix 1. Devices and Procedures

Appendix 2. Search Strategies

Appendix 3. Abstract Inclusion/Exclusion Criteria

Appendix 4. Quality Rating Criteria

Appendix 6. Expert Reviewers

Appendix 7. Literature Concordance with the Canadian Task Force on Preventive Health Care Review