# References

1 Schuster MA. Developmental screening. In: McGlynn EA, ed. Quality of care for children and adolescents: A review of selected clinical conditions and quality indicators. Santa Monica, CA: RAND; 2000:157–168.
2 Catts HW, Fey ME, Tomblin JB, Zhang X. A longitudinal investigation of reading outcomes in children with language impairments. J Speech Lang Hear Res. 2002;45(6):1142-1157. [pmid: 12546484].
3 Scarborough HS, Dobrich W. Development of children with early language delay. J Speech Hear Res. 1990;33(1):70-83. [pmid: 2314086].
4 Richman N, Stevenson J, Graham PJ. Pre-school to school: A behavioural study. Behavioural Development: A Series of Monographs. 1982:228.
5 Silva PA, Williams SM, McGee R. A longitudinal study of children with developmental language delay at age three: later intelligence, reading and behaviour problems. Dev Med Child Neurol. 1987;29:630-640. [pmid: 2444484].
6 Bishop D, Clarkson B. Written language as a window into residual language deficits: a study of children with persistent and residual speech and language impairments. Cortex. 2003;39:215-237. [pmid: 12784886].
7 Stern LM, Connell TM, Lee M, Greenwood G. The Adelaide preschool language unit: results of follow-up. J Paediatr & Child Health. 1995;31(3):207-212. [pmid: 7669381].
8 Welcome to ASHA. Available at: http://www.asha.org. Accessed 11 Nov, 2004.
9 Law J, Boyle J, Harris F, Harkness A, Nye C. Screening for primary speech and language delay: a systematic review of the literature. Int J Lang Commun Disord. 1998;33(Suppl):21-23. [pmid: 10343657].
10 Randall D, Reynell J, Curwen M. A study of language development in a sample of 3 year old children. Br J Disord Commun. 1974;9(1):3-16. [pmid: 4433458].
11 Burden V, Stott CM, Forge J, Goodyer I. The Cambridge Language and Speech Project (CLASP). I .Detection of language difficulties at 36 to 39 months. Dev Med Child Neurol. 1996;38(7):613-631. [pmid: 8674912].
12 Rescorla L, Hadicke-Wiley M, Escarce E. Epidemiological investigation of expressive language delay at age two. First Language. 1993;13:5-22.
13 Silva PA, McGee R, Williams SM. Developmental language delay from three to seven years and its significance for low intelligence and reading difficulties at age seven. Dev Med Child Neurol. 1983;25(6):783-793. [pmid: 6653911].
14 Stevenson J, Richman N. The prevelence of language delay in a population of three-year-old children and its association with general retardation. Dev Med Child Neurol. 1976;18:431-441. [pmid: 955307].
15 Wong V, Lee PWH, Mak-Lieh F, et al. Language screening in preschool Chinese children. Eur J Disord Commun. 1992;27(3):247-264. [pmid: 1306390].
16 Roulstone S, Peters TJ, Glogowska M, Enderby P. A 12-month follow-up of preschool children investigating the natural history of speech and language delay. Child: Care, Health & Dev. 2003;29(4):245-255.
17 Bashir AS, Scavuzzo A. Children with language disorders: natural history and academic success. Journal of Learning Disabilities. 1992;25(1):53-65. discussion 66–70. [pmid: 1740638].
18 Young AR, Beitchman JH, Johnson C, et al. Young adult academic outcomes in a longitudinal sample of early identified language impaired and control children. J Child Psychol Psychiatry. 2002;43(5):635-645. [pmid: 12120859].
19 Felsenfeld S, Broen PA, McGue M. A 28-year follow-up of adults with a history of moderate phonological disorder: educational and occupational results. J Speech Hear Res. 1994;37:1341-1353. [pmid: 7877292].
20 Cohen NJ, Barwick MA, Horodezky N, Vallance DD, Im N. Language, achievement, and cognitive processing in psychiatrically disturbed children with previously identified and unsuspected language impairments. J Child Psychol Psychiatry. 1998;39(865877).
21 Cohen NJ, Menna R, Vallance DD, Barwick MA, Im N, Horodezky N. Language, social cognitive processing, and behavioral characteristics of psychiatrically disturbed children with previously identified and unsuspected language impairments. J Child Psychol Psychiatry. 1998;39:853-864. [pmid: 9758194].
22 American Academy of Pediatrics. Guidelines for Health Supervision III. Elk Grove Village, IL; 1997.
23 Bricker D, Squires J. Ages & Stages Questionnaires: A parent-completed, child-monitoring system. 2nd ed: Paul H. Brookes Publishing Company; 1999.
24 Capute AJ, Palmer FB, Shapiro BK, Wachtel RC, Schmidt S, Ross A. Clinical linguistic and auditory milestone scale: prediction of cognition in infancy. Dev Med Child Neurol. 1986;28(6):762-771. [pmid: 3817315].
25 Frankenburg WK, Dodds J, Archer P, Shapiro H, Bresnick B. The Denver II: a major revision and restandardization of the Denver Developmental Screening Test. Pediatrics. 1992;89(1):91-97. [pmid: 1370185].
26 Fenson L, Pethick SJ, Renda C, Cox JL, Dale PS, Reznick JS. Short-form versions of the MacArthur Communicative Development Inventories. Applied Psycholinguistics. 2000;21:95116.
27 Coulter L, Gallagher C. Piloting new ways of working: evaluation of the WILSTAAR Programme. Int J Lang Commun Disord. 2001;36(Suppl):270-275. [pmid: 11340795].
28 Fluharty, NB. The design and standardization of a speech and language screening test for use with preschool children. J Speech Hear Disord. 1973;39:75-88. [pmid: 4814827].
29 Coplan J, Gleason JR, Ryan R, Burke MG, Williams ML. Validation of an early language milestone scale in a high-risk population. Pediatrics. 1982;70(5):677-683. [pmid: 7133817].
30 Ireton H, Glascoe FP. Assessing children's development using parents' reports: the child development inventory. Clin Pediatr. 1995;34:248-255.
31 Feightner JW. Preschool screening for developmental problems. Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventive Health Care. Ottawa: Health Canada; 1994:290–296.
32 American Academy of Pediatrics. Developmental surveillance and screening of infants and young children. Pediatrics. 2001;108(1):192-196. [pmid: 11433077].
33 Johns Hopkins Hospital Children's Medical and Surgical Center. The Harriet Lane Handbook. A manual for pediatric house officers. 16th ed. Philadelphia, PA: Mosby; 2002.
34 American Academy of Child and Adolescent Psychiatry. Practice parameters for the assessment and treatment of children and adolescents with language and learning disorders. J Am Acad Child Adolesc Psychiatry. 1998;37(10 Suppl):46S-62S. [pmid: 9785728].
35 Halfon N, et al. Summary statistics from the National Survey of Early Childhood Health, 2000. National Center for Health Statistics. Vital and Health Statistics. 2002;15(4).
36 Law J, Garrett Z, Nye C. Speech and language therapy interventions for children with primary speech and language delay or disorder. Cochrane Database Syst Rev. 2003(3):CD004110.
37 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force. A review of the process. Am J Prev Med. 2001;30(3S):21-35. [pmid: 11306229].
38 Brookhouser PE, Hixson PK, Matkin ND. Early childhood language delay: the otolaryngologist's perspective. Laryngoscope. 1979;89(12):1898-1913. [pmid: 513912].
39 Campbell TF, Dollaghan CA, Rockette HE, et al. Risk factors for speech delay of unknown origin in 3-year-old children. Child Dev. 2003;74(2):346-357. [pmid: 12705559].
40 Cantwell DP, Baker L. Psychiatric and learning disorders in children with speech and language disorders: a descriptive analysis. Adv in Learning & Behav Disabilities. Original Search 1-23-04 1985;4.
41 Choudhury N, Benasich AA. A family aggregation study: the influence of family history and other risk factors on language development. J Speech Lang Hear Res. 46(2):261-272. [pmid: 14700370].
42 Singer LT, Siegel AC, Lewis B, Hawkins S, Yamashita T, Baley J. Preschool language outcomes of children with history of bronchopulmonary dysplasia and very low birth weight. J Dev Behav Pediatr. 2001;22(1):19-26. [pmid: 11265919].
43 Tallal P, Ross R, Curtiss S. Familial aggregation in specific language impairment. J Speech Hear Disord. 1989;54(2):167-173. [pmid: 2709834].
44 Tomblin JB, Hardy JC, Hein HA. Predicting poor-communication status in preschool children using risk factors present at birth. J Speech Hear Res. 1991;34(5):1096-1105. [pmid: 1749241].
45 Tomblin J, Smith E, Zhang X. Epidemiology of specific language impairment: prenatal and perinatal risk factors. J Commun Disord. 1997;30(4):325-344. [pmid: 9208366].
46 Whitehurst GJ, Arnold DS, Smith M, Fischel JE, Lonigan CJ, Valdez-Menchaca MC. Family history in developmental expressive language delay. J Speech Hear Res. 1991;34(5):1150-1157. [pmid: 1749245].
47 Fox A, Dodd B, Howard D. Risk factors for speech disorders in children. Int J Lang Commun Disord. 2002;37(2):117-131. [pmid: 12012611].
48 Klein PS, Tzuriel D. Preschoolers' type of temperament as predictor of potential difficulties in cognitive functioning. Isr J Psychiatry Relat Sci. 1986;23(1):49-61. [pmid: 3759393].
49 Kloth S, Janssen P, Kraaimaat F, Brutten G. Communicative behavior of mothers of stuttering and nonstuttering high-risk children prior to the onset of stuttering. J Fluency Disord. 1995;20(4):365-377.
50 Lyytinen H, Ahonen T, Eklund K, et al. Developmental pathways of children with and without familial risk for dyslexia during the first years of life. Dev Neuropsychol. 2001;20(2):535-554. [pmid: 11892951].
51 Peters SA, Grievink EH, van Bon WH, van den Bercken JH, Schilder AG. The contribution of risk factors to the effect of early otitis media with effusion on later language, reading and spelling. Dev Med Child Neurol. 1997;39(1):31-39. [pmid: 9003727].
52 Weindrich D, Jennen-Steinmetz C, Laucht M, Esser G, Schmidt MH. Epidemiology and prognosis of specific disorders of language and scholastic skills. Eur Child Adolesc Psychiatry. 2000;9(3):186-194. [pmid: 11095041].
53 Yliherva A, Olsen P, Maki-Torkko E, Koiranen M, Jarvelin MR. Linguistic and motor abilities of low-birthweight children as assessed by parents and teachers at 8 years of age.[comment]. Acta Paediatr. 2001;90(12):1440-1449. [pmid: 11853344].
54 Klee T, Pearce K, Carson DK. Improving the positive predictive value of screening for developmental language disorder. J Speech Lang Hear Res. 2000;43(4):821-833. [pmid: 11386471].
55 Leppert ML, Shank TP, Shapiro BK, Capute AJ. The capute scales: CAT/CLAMS—A pediatric assessment tool for the early detection of mental retardation and communicative disorders. Ment Retard Dev Disabil Res Rev. 1998;4(1):14-19.
56 Macias MM, Saylor CF, Greer MK, Charles JM, Bell N, Katikaneni LD. Infant screening: the usefulness of the Bayley Infant Neurodevelopmental Screener and the Clinical Adaptive Test/Clinical Linguistic Auditory Milestone Scale. J Dev Behav Pediatr. 1998;19(3):155-161. [pmid: 9648040].
57 Oakenfull S, McGregor T, Ramtin F, Stanhope J, Zinzan S. Re: WILSTAAR.[comment]. Int J Lang Commun Disord. 2001;36(1):135-138. [pmid: 11221430].
58 Rescorla L, Alley A. Validation of the language development survey (LDS): a parent report tool for identifying language delay in toddlers. J Speech Lang Hear Res. 2001;44(2):434-445. [pmid: 11324663].
59 Rescorla L, Achenbach TM. Use of the Language Development Survey (LDS) in a national probability sample of children 18 to 35 months old. J Speech Lang Hear Res. 2002;45(4):733-743. [pmid: 12199403].
60 Sherman T, Shulman BB, Trimm RF, Hoff C. Plaster: predicting communication impairments in a NICU follow-up population...Pediatric Language Acquisition Screening Tool for Early Referral. Infant-Toddler Interventions: the Transdisciplinary Journal. 1996;6(3):183-195.
61 Stott CM, Merricks MJ, Bolton PF, Goodyer IM. Screening for speech and language disorders: the reliability, validity and accuracy of the General Language Screen. Int J Lang Commun Disord. 2002;37(2):133-151. [pmid: 12012612].
62 Ward S. Detecting abnormal auditory behaviours in infancy: the relationship between such behaviours and linguistic development. Br J Disord Commun. 1984;19:237-251. [pmid: 6508994].
63 Black MM, Gerson LF, Freeland CA, Nair P, Rubin JS, Hutcheson JJ. Language screening for infants prone to otitis media. J Pediatr Psychol. 1988;13(3):423-433. [pmid: 3199297].
64 Borowitz KC, Glascoe FP. Sensitivity of the Denver Developmental Screening Test in speech and language screening. Pediatrics. 1986;78(6):1075-1078. [pmid: 3786032].
65 Clark JG, Jorgensen SK, Blondeau R. Investigating the validity of the clinical linguistic auditory milestone scale. Int J Pediatr Otorhinolaryngol. 1995;31:63-75. [pmid: 7537257].
66 German ML, Williams E, Herzfeld J, Marshall R. Utility of the Revised Denver Developmental Screening Test and the Developmental Profile II in identifying preschool children with cognitive, language, and motor problems. Education and Training of the Mentally Retarded. 1982;17(4):319-324.
67 Glascoe FP. Can clinical judgment detect children with speech-language problems?. Pediatr. 1991;87(3):317-322.
68 Glascoe FP, Byrne KE. The accuracy of three developmental screening tests. J Early Interv. 1993;17(4):368-379.
69 Klee T, Carson DK, Gavin WJ, Hall L, Kent A, Reece S. Concurrent and predictive validity of an early language screening program. J Speech Lang Hear Res. Update Search 1998;41(3):627–641.
70 McGinty C. An investigation into aspects of the Mayo early language screening test. Child: Care, Health & Dev. 2000;26(2):111-128.
71 Rescorla L. The Language Development Survey: a screening tool for delayed language in toddlers. J Speech Hear Disord. 1989;54(4):587-599. [pmid: 2811339].
72 Scherer NJ, D'Antonio LL. Parent questionnaire for screening early language development in children with cleft palate. Cleft Palate-Craniofacial J. 1995;32(1):7-13.
73 Allen DV, Bliss LS. Concurrent validity of two language screening tests. J Commun Disord. 1987;20(4):305-317. [pmid: 3624526].
74 Drumwright A, Van Natta P, Camp B, Frankenburg W, Drexler H. The Denver articulation screening exam. J Speech Hear Disord. 1973;38(1):3-14. [pmid: 4698385].
75 Laing GJ, Law J, Levin A, Logan S. Evaluation of a structured test and a parent led method for screening for speech and language problems: prospective population based study. BMJ. 2002;325(7373):1152-1154. [pmid: 12433766]. [pmcid: 133455].
76 Blaxley L, Clinker M, Warr-Leeper GA. Two language screening tests compared with developmental sentence scoring. Language, Speech, and Hearing Services in the Schools. 1983;14:38-46.
77 Bliss LS, Allen DV. Screening kit of language development: a preschool language screening instrument. J Commun Disord. 1984;17(2):133-141. [pmid: 6725626].
78 Chaffee CA, Cunningham CE, Secord-Gilbert M, Elbard H, Richards J. Screening effectiveness of the Minnesota Child Development Inventory Expressive and Receptive Language Scales: sensitivity, specificity, and predictive value. Psychol Assess: A J of Cons and Clin Psychol. 1990;2(1):80-85.
79 Dixon J, Kot A, Law J. Early language screening in City and Hackney: work in progress. Child: Care, Health & Dev. 1988;14:213-229.
80 Law J. Early language screening in City and Hackney: the concurrent validity of a measure designed for use with 2 1/2-year-olds. Child: Care, Health & Dev. 1994;20(5):295-308.
81 Levett L, Muir J. Which three year olds need speech therapy? Uses of the Levett-Muir language screening test. Health Visitor. 1983;56(12):454-456. [pmid: 6559779].
82 Stokes SF. Secondary prevention of paediatric language disability: A comparison of parents and nurses as screening agents. Eur J Disord Commun. 1997;32(2, Spec Iss):139-158. [pmid: 9279431].
83 Sturner RA, Heller JH, Funk SG, Layton TL. The Fluharty Preschool Speech and Language Screening Test: a population-based validation study using sample-independent decision rules. J Speech Hear Res. 1993;36(4):738-745. [pmid: 8377486].
84 Walker D, Gugenheim S, Downs MP, Northern JL. Early Language Milestone Scale and language screening of young children.[comment]. Pediatr. 1989;83(2):284-288.
85 Alberts FM, Davis BL, Prentice L. Validity of an observation screening instrument in a multicultural population. Journal of Early Intervention. 1995;19(2):168-177.
86 Conti-Ramsden G. Processing and linguistic markers in young children with specific language impairment (SLI). J Speech Lang Hear Res. 2003;46(5):1029-1037. [pmid: 14575341].
87 Gray S. Diagnostic accuracy and test-retest reliability of nonword repetition and digit span tasks administered to preschool children with specific language impairment. J Commun Disord. 2003;36(2):129-151. [pmid: 12609578].
88 Merrell AW, Plante E. Norm-referenced test interpretation in the diagnostic process. Language, Speech, and Hearing Services in the Schools. 1997;28(1):50-58.
89 Plante E, Vance R. Diagnostic accuracy of two tests of preschool language. Am J Speech Lang Pathol. 1995;4(2):70-76.
90 Wilcox LD, Anderson RT. Distinguishing between phonological difference and disorder in children who speak African-American vernacular English: an experimental testing instrument. J Commun Disord. 1998;31(4):315-335. [pmid: 9697042].
91 Dodge GR. A comparison of language screening methods. Language, Speech, and Hearing Services in the Schools. 1980;11(4):214-217.
92 Feeney J, Bernthal J. The efficiency of the revised Denver Developmental Screening Test as a language screening tool. Language, Speech, and Hearing Services in the Schools. 1996;27(4):330-332.
93 Sturner RA, Funk SG, Green JA. Preschool speech and language screening: further validation of the sentence repetition screening test. J Dev Behav Pediatr. 1996;17(6):405-413. [pmid: 8960570].
94 Glogowska M, Roulstone S, Enderby P, Peters TJ. Randomised controlled trial of community based speech and language therapy in preschool children. BMJ. 2000;321(7266):923-926. [pmid: 11030677]. [pmcid: 27499].
95 Almost D, Rosenbaum P. Effectiveness of speech intervention for phonological disorders: a randomized controlled trial.[erratum appears in Dev Med Child Neurol 1998 Oct;40(10):719]. Dev Med Child Neurol. 1998;40(5):319-325. [pmid: 9630259].
96 Barratt J, Littlejohns P, Thompson J. Trial of intensive compared to weekly speech therapy in preschool children. Archives of Disease in Childhood. 1992;671:106-108. [pmid: 1739321].
97 Cole KN, Dale PS. Direct language instruction and interactive language instruction with language delayed preschool children: a comparison study. J Speech Hear Res. 1986;29(2):206-217. [pmid: 3724113].
98 Courtright JA, Courtright IC. Imitative modeling as a language intervention strategy: the effects of two mediating variables. J Speech Hear Res. 1979;22(2):389-402. [pmid: 491564].
99 Gibbard D. Parental-based intervention with pre-school language-delayed children. Eur J Disord Commun. 1994;29(2):131-150. [pmid: 7865920].
100 Girolametto L, Pearce PS, Weitzman E. Interactive focused stimulation for toddlers with expressive vocabulary delays. J Speech Hear Res. 1996;39(6):1274-1283. [pmid: 8959612].
101 Girolametto L, Pearce PS, Weitzman E. Effects of lexical intervention on the phonology of late talkers. J Speech Lang Hear Res. 1997;40(2):338-348. [pmid: 9130202].
102 Robertson SB, Weismer SE. Effects of treatment on linguistic and social skills in toddlers with delayed language development. J Speech Lang Hear Res. 1999;42(5):1234-1248. [pmid: 10515518].
103 Robertson SB, Weismer SE. The influence of peer models on the play scripts of children with specific language impairment. J Speech Lang Hear Res. 1997;40(1):49-61. [pmid: 9113858].
104 Rvachew S, Nowak M. The effect of target-selection strategy on phonological learning. J Speech Lang Hear Res. 2001;44:610-623. [pmid: 11407566].
105 Shelton RL, Johnson AF, Ruscello DM, Arndt WB. Assessment of parent-administered listening training for preschool children with articulation deficits. J Speech Hear Disord. 1978;43(2):242-254. [pmid: 661262].
106 Wilcox MJ, Kouri TA, Caswell SB. Early language intervention: a comparison of classroom and individual treatment. Am J Speech-Lang Path. 1991;1(1):49-61.
107 Law J, Kot A, Barnett G. A comparison of two methods for providing intervention to three year old children with expressive/receptive language impairment. London: Department of Language and Communication Science, City University; 1999. 002.
108 Fey ME, Cleave PL, Ravida AI, L SH, Dejmal AE, Easton DL. Effects of grammar facilitation on phonological performance of children with speech and language impairments. J Speech Hear Res. 1994;37:594-607. [pmid: 8084191].
109 Fey ME, Cleave PL, Long SH. Two models of grammar facilitation in children with language impairments: phase 2. J Speech Lang Hear Res. 1997;40(1):5-19. [pmid: 9113855].
110 Mulac A, Tomlinson CN. Generalization of an operant remediation program for syntax with language delayed children. J Commun Disord. 1977;10(3):231-243. [pmid: 903408].
111 Ruscello DM, Cartwright LR, Haines KB, Shuster LI. The use of different service delivery models for children with phonological disorders. J Commun Disord. 1993;26(3):193-203. [pmid: 8227504].
112 Rvachew S. Speech perception training can facilitate sound production learning. J Speech Hear Res. 1994;37(2):347-357. [pmid: 8028316].
113 Schwartz RG, Chapman K, Terrell BY, Prelock P, Rowan L. Facilitating word combination in language-impaired children through discourse structure. J Speech Hear Disord. 1985;50(1):31-39. [pmid: 3974209].
114 Fey ME, Cleave PL, Long SH, Hughes DL. Two approaches to the facilitation of grammar in children with language impairment: an experimental evaluation. J Speech Hear Res. 1993;36(1):141-157. [pmid: 7680731].
115 Girolametto L, Pearce PS, Weitzman E. The effects of focused stimulation for promoting vocabulary in young children with delays: a pilot study. J Child Commun Dev. 1996;17(2):39-49.
116 Glogowska M, Campbell R, Peters TJ, Roulstone S, Enderby P. A multimethod approach to the evaluation of community preschool speech and language therapy provision. Child: Care, Health & Dev. 2002;28(6):513-521.
117 Reid J, Donaldson ML. The effectiveness of therapy for child phonological disorder: the Metaphon approach. In: Aldridge M, ed. Child Language. Clevedong, Avon: Multiligual Matters; 1996.
118 Sutton L, Tapper L. Investigating WILSTAAR. Bulletin of the Royal College of Speech and Language Therapists. 1999;August.
119 King TM, Glascoe FP. Developmental surveillance of infants and young children in pediatric primary care. Current Opinion in Pediatrics. 2003;15(6):624-629. [pmid: 14631210].