# Acknowledgements

This Evidence Synthesis was funded by the Agency for Healthcare Research and Quality (AHRQ) for the U.S. Preventive Services Task Force (USPSTF), and the investigators acknowledge the contributions of Janelle Guirguis-Blake, MD, and David Lanier, MD, Task Order Officers, AHRQ, and Iris Maybry, MD, Medical Officer, AHRQ. Members of the USPSTF who served as leads for this project include Alfred Berg, MD, MPH, Paul Frame, MD, Leon Gordis, MD, DrPH, Jonathan Klein, MD, MPH, Virginia Moyer, MD, MPH, and Barbara Yawn, MD, MSc. Investigators thank the expert reviewers commenting on draft versions (Appendix 1) and Andrew Hamilton, MLS, MS for conducting the literature searches.

## Requests for Reprints

Reprints are available from the AHRQ Web site at www.ahrq.gov (click on Preventive Services).