# Preface

The agency for Healthcare Research and Quality (AHRQ) sponsors the development of Evidence Syntheses through its Evidence-based Practice Program. With guidance from the U.S. Preventive Services Task Force^*^ (USPSTF) and input from Federal partners and primary care specialty societies, the Evidence-based Practice Center at the Oregon Health & Science University systematically reviews the evidence of the effectiveness of a wide range of clinical preventive services, including screening, counseling, and chemoprevention, in the primary care setting. The Evidence Syntheses—comprehensive reviews of the scientific evidence on the effectiveness of particular clinical preventive services—serve as the foundation for the recommendations of the USPSTF, which provide age- and risk-factor-specific recommendations for the delivery of these services in the primary care setting. Details of the process of identifying and evaluating relevant scientific evidence are described in the “Methods” section of each Evidence Synthesis.

* The USPSTF is an independent panel of experts in primary care and prevention first convened by the U.S. Public Health Service in 1984. The USPSTF systematically reviews the evidence on the effectiveness of providing clinical preventive services—including screening, counseling, and chemoprevention—in the primary care setting. AHRQ convened the USPSTF in November 1998 to update existing Task Force recommendations and to address new topics.

The Evidence Syntheses document the evidence regarding the benefits, limitations, and cost-effectiveness of a broad range of clinical preventive services and will help further awareness, delivery, and coverage of preventive care as an integral part of quality primary health care.

AHRQ disseminates the Evidence Syntheses on the AHRQ Web site (http://www.ahrq.gov/clinic/uspstfix.htm) along with recommendations of the USPSTF. The Recommendation Statements are also available through the National Guideline Clearinghouse (http://www.ngc.gov).

We welcome written comments on this Evidence Synthesis. Comments may be sent to: Director, Center fro Primary Care, Prevention, and Clinical Partnerships, Agency for Healthcare Research and Quality, 540 Gaither Road, Rockville, MD 20850.

- Carolyn Clancy, M.D.
- Director
- Agency for Healthcare Research and Quality

- Helen Burstin, M.D., M.P.H.
- Director
- Center for Primary Care, Prevention, and Clinical Partnerships
- Agency for Healthcare Research and Quality