# Discussion

## Conclusions

Results of the evidence synthesis are summarized in Table 8 by key question. Studies are not available addressing the overarching key question about the effectiveness of screening (key question 1), adverse effects of screening (key question 3), the role of enhanced surveillance in primary care (key question 4), long-term effectiveness of interventions on non-speech and language outcomes for children identified with delay (key questions 7), and adverse effects of interventions (key question 8). No studies determine the optimal ages and frequency for screening (key question 2d). Relevant studies are available regarding the use of risk factors for screening (key question 2a), techniques for screening (key question 2b and 2c), and effectiveness of interventions on short-term speech and language and non-speech and language outcomes for children identified with delay (key questions 5 and 6).

Table 8 Summary of Evidence

Key Question | Level of Evidence | Conclusions | USPSTF Quality | Generalizability
1. Does screening for speech and language delay result in improved speech and language as well as improved other non speech and language outcomes? | No studies
2. Do screening evaluations in the primary care setting accurately identify children for diagnostic evaluation and interventions?
2a. Does identification of risk factors improve screening? | Observational studies (II) | Studies of risk factors are heterogeneous and results are inconsistent. A list of specific risk factors to guide primary care physicians in selective screening has not been developed or tested. The most consistent risk factors include a family history of speech and language delay and learning difficulties, sex, and perinatal factors, however their role in screening is unclear | Not rated (most cross-sectional design) | Fair-good
2b & c. What are screening techniques and how do they differ by age? What is the accuracy of screening techniques and how does it differ by age? | Observational studies (II) | Many instruments are available, but no gold standard has been developed and tested for screening, reference standards vary across studies, few studies compare the performance of 2 or more screening techniques in one population, and comparisons of a single screening technique across different populations are lacking. Optimal methods have not been established. Brief instruments (≤10 minutes) administered by professionals and nonprofessionals are available, sensitivity and specificity vary, and most studies do not provide enough information to determine how accuracy varies by age | Fair-good | Fair
2d. What are the optimal ages and frequency for screening? | No studies
3. What are the adverse effects of screening? | No studies
4. What is the role of enhanced surveillance by primary care clinicians? | No studies
5. Do interventions for speech and language delay improve speech and language outcomes? | RCTs (I) | Fourteen good and fair-quality randomized controlled trials of interventions reported significantly improved speech and language outcomes compared to control groups. Improvement was demonstrated in several domains among children in all age groups studied and across multiple therapeutic settings. Studies were small, heterogeneous, and reported short-term outcomes based on various instruments and measures. As a result, long-term outcomes are not known, interventions could not be directly compared, and generalizability is questionable | Fair-good | Poor-fair
6. Do interventions for speech and language delay improve other non speech and language outcomes? | RCTs (I) | Improvement in other functional outcomes, such as socializations skills, self-esteem, and improved play themes, were demonstrated in some, but not all, of the four studies measuring them | Fair-good | Poor -fair
7. Does improvement in speech and language outcomes lead to improved additional outcomes? | No studies
8. What are the adverse effects of interventions? | No studies
9. What are cost effectiveness issues? | No studies

The use of risk factors for selective screening has not been evaluated and a list of specific risk factors to guide primary care physicians has not been developed or tested. Sixteen studies about potential risk factors for speech and language delay in children enrolled heterogeneous populations, had dissimilar inclusion and exclusion criteria, and measured different risk factors and outcomes. The most consistently reported risk factors included a family history of speech and language delay, male sex, and perinatal factors. Other risk factors reported less consistently included educational levels of the mother and father, childhood illnesses, birth order, and family size.

The performance characteristics of 51 evaluations using 32 instruments taking 30 minutes or less to administer were described in 44 studies relevant to screening. Studies utilizing evaluations taking 10 minutes or less and rated good to fair in quality reported wide ranges of sensitivity and specificity when compared to reference standards (sensitivity 17% to 100%; specificity 45% to 100%). In these studies, instruments providing the highest sensitivity and specificity included the Early Language Milestone Scale, Clinical Linguistic and Auditory Milestone Scale, Language Development Survey, Screening Kit of Language Development, and the Levett-Muir Language Screening Test. Most of the evaluations, however, were not designed for screening purposes, instruments measured different domains, and the study populations and settings were often outside primary care. No gold standard has been developed and tested for screening, reference standards varied across studies, few studies compared the performance of 2 or more screening techniques in one population, and comparisons of a single screening technique across different populations are lacking. The optimal methods and ages for screening cannot be determined from these studies.

Randomized controlled trials of multiple types of interventions reported significantly improved speech and language outcomes compared to control groups. Improvement was demonstrated in several domains including articulation, phonology, expressive language, receptive language, lexical acquisition, and syntax among children in all age groups studied and across multiple therapeutic settings. However, studies were small, heterogeneous, may be subject to plateau effects, and reported short-term outcomes based on various instruments and measures. As a result, long-term outcomes are not known, interventions could not be directly compared to determine optimal approaches, and generalizability is questionable.

## Limitations of the Literature

There are many limitations of the literature relevant to screening for speech and language delay in preschool age children including lack of studies specific to screening as well as difficulties inherent in this area of research. This evidence review is limited by use of only published studies of instruments and interventions. Data about performance characteristics of instruments, in particular, are not generally accessible and are often only available in manuals that must be purchased. Interventions vary widely and may not be generalizable. In addition, studies from countries with different health care systems, such as the U.K., may not translate well to U.S. practice.

Although speech and language development is multi-dimensional, the individual constructs that comprise it are often assessed separately. Numerous evaluation instruments and interventions accommodating children across a wide range of developmental stages have been developed to identify and treat specific abnormalities of these functions. As a result, studies include many different instruments and interventions that are most often designed for purposes other than screening. Also, studies of interventions typically focus on one or a few interventions. In clinical practice, children are provided with individualized therapies consisting of multiple interventions. The effectiveness of these complex interventions may be difficult to evaluate. Adapting results of this heterogeneous literature to determine benefits and adverse effects of screening is problematic. Also, behavioral interventions are difficult to conduct in long-term randomized trials, and it is not possible to blind parents or clinicians. Randomizing children to therapy or control groups when clinical practice standards support therapy raise ethical dilemmas.

Speech and language delay is defined by measurements on diagnostic instruments in terms of a position on a normal distribution. Measures and terminology are inconsistently used and there is no recognized gold standard. This is challenging when defining cases and determining performance characteristics of screening instruments in studies.

Identification of speech and language delay may be associated with benefits and adverse effects that would not be captured by studies of clinical or health outcomes. The process of screening alerts physicians and caretakers to developmental milestones and focuses attention on the child's development, potentially leading to increased surveillance, feelings of caregiver support, and improved child self esteem. Alternatively, caretakers and children may experience increased anxiety and stress during the screening and evaluation process. Detection of other conditions during the course of speech and language evaluation, such as hearing loss, is an unmeasured benefit if appropriate interventions can improve the child's status.

Identification of speech and language delay may be associated with benefits and adverse effects that would not be captured by studies of clinical or health outcomes. The process of screening alerts physicians and caretakers to developmental milestones and focuses attention on the child's development, potentially leading to increased surveillance, feelings of caregiver support, and improved child self esteem. Alternatively, caretakers and children may experience increased anxiety and stress during the screening and evaluation process. Detection of other conditions during the course of speech and language evaluation, such as hearing loss, is an unmeasured benefit if appropriate interventions can improve the child's status.

## Future Research

Future research should focus on determining optimal approaches of identifying preschool age children with speech and language delay in primary care settings who would be appropriate candidates for further evaluations and possibly speech and language interventions. These approaches should be integrated into routine developmental surveillance practices of clinicians caring for children.^119^ Studies evaluating the effectiveness of validated brief screening instruments that include child and caretaker components could lead to a more standardized approach. Studies of specific speech and language components of currently available broad developmental screening instruments, such as Ages and Stages, would be useful. Incorporation of risk factors and parent report in studies of screening approaches could provide information about their added value. Additional studies that compare screening instruments and methods in large primary care populations could lead to defining gold standards and acceptable referral criteria. Evaluating these in different populations of children would minimize cultural and language biases.

Future research should determine the benefits and adverse effects of undergoing screening, diagnostic evaluation, and treatment, and how these impact later development. Translational studies of professional guidelines, Bright Futures, Centers for Disease Control and Prevention goals, and others would be useful to determine the feasibility and impact of screening. Further work about the effectiveness of interventions, including speech and language domain specific results, may provide new insights. School-based efforts could be designed to complement strategies developed for young children improving long term outcomes. Results of these studies may help determine optimal ages and intervals for screening. Functional long term outcomes such as school performance and social adjustment need to be more thoroughly addressed.