# Results

## Key Question 1. Does Screening for Speech and Language Delay Result in Improved Speech and Language as well as Improved Other Non-speech and Language Outcomes?

No studies addressed this question.

## Key Question 2. Do Screening Evaluations in the Primary Care Setting Accurately Identify Children for Diagnostic Evaluation and Interventions?

## 2a. Does Identification of Risk Factors Improve Screening?

A total of 246 abstracts about risk factors for speech and language delay were identified from literature searches, and 78 full text papers were reviewed. Nine studies conducted in English speaking populations,^38^–^46^ and 7 studies from non-English speaking populations^47^–^53^ met inclusion criteria (Table 3; Appendix 6).

Table 3 Summary of Studies of Risk Factors

Author, Year | Population | Age Range (Months) | Speech & Language Domains | Family History | Male Sex | SES | Birth Order | Perinatal Factors | Parental Education | Medical Conditions | Other Associations
English Language
Brookhouser, 1979^38^ | 24 referred from Boys Town Institute | 28–62 | Language | 0 | NR | NR | NR | NR | NR | X | NR
Campbell, 2003^39^ | 398 cases and 241 controls from a large, prospective study in Pittsburgh, PA | 36 | Speech | X | X | X | NR | NR | X | NR | NR
| | | | | | | | | Mother
Cantwell, 1985^40^ | 600 children referred from a speech and hearing clinic in Los Angeles, CA | 20–191 | Multiple types | NR | NR | NR | NR | NR | NR | NR | X
| | | | | | | | | | | Psychiatric, behavioral, or developmental disorder
Choudhury, 2003^41^ | 42 cases with positive family histories and 94 controls from New York City, NY area | 36 | Language | X | X | 0 | NR | NR | 0 | 0 | X
| | | | | | | | | Mother or father | Asthma | Older parents, more children in family
Singer, 2001^42^ | 98 cases (VLBW/BPD), 70 VLBW/non BPD controls, and 95 term controls from Cleveland, OH region hospitals | 36 | Language | NR | NR | X | NR | NR | NR | X | X
| | | | | | | | | | BPD, PDA | Neurologic risk, minority race
Tallal, 1989^43^ | 76 cases and 54 controls from the San Diego, CA Longitudinal Study | 48–59 | Language | X | NR | NR | NR | NR | X | NR | NR
| | | | | | | | | Mother or father
Tomblin, 1991^44^ | 662 from a longitudinal cohort | 30–60 | Speech and language | X | X | NR | X | NR | 0 | NR | NR
| | | | | | | Born later | | Mother
| | | | | | | | | X
| | | | | | | | | Father
Tomblin, 1997^45^ | 177 cases and 925 controls from metro regions of Iowa or Illinois | Kinder-garten age | Speech and language | X | NR | NR | NR | 0 | X | NR | X
| | | | | | | | Low birth weight | Mother or father | | Younger mother, less breastfeeding
Whitehurst, 1991^46^ | 62 cases and 55 controls from Long Island, NY | 24–38 | Expressive language | 0 | NR | NR | NR | NR | NR | NR | NR
Non-English Language
Fox, 2002^47^ (Germany) | 65 cases and 48 controls | 32–86 | Speech | X | NR | NR | NR | X | NR | NR | NR
| | | | | | | | Birth difficulties, sucking habits
Klein, 1986^48^ (Israel) | 72 kindergarten children from a middle-class urban area | 48–108 | Vocabulary | NR | NR | NR | NR | NR | NR | NR | 0
| | | | | | | | | | | Child's behavior
Kloth, 1995^49^ (Netherlands) | 93 referred because one or both parents were stutterers or had a history of stuttering | 23–58 | Stuttering | NR | NR | NR | NR | NR | NR | NR | 0
| | | | | | | | | | | Mother stutters, speaking style or rate
Lyytinen, 2001^50^ (Finland) | 107 with familial risk of dyslexia and 93 without | 0–54 | Speech and language | X | NR | NR | NR | NR | NR | NR | NR
Peters, 1997^51^ (Netherlands) | 946 from a Dutch birth cohort in Nijmegen | 84–96 | Language and educational attainment | NR | 0 | NR | NR | 0 | X | NR | X
| | | | | | | | Preterm or low birth weight | | | Dutch as a second language
Weindrich, 2000^52^ (Germany) | 320 recruited at birth at a German hospital | Tested at 54 and 96 months | Receptive and expressive language and articulation (54 months); reading and spelling (96 months) | NR | NR | NR | NR | X | X | NR | X
| | | | | | | | Preterm, toxemia, low birth weight | Mother or father | | Parental psychiatric disorder, overcrowding, parental broken home or delinquency, one-parent family, unwanted pregnancy
Yliherva, 2001^53^ (Finland) | 8,370 recruited at birth from 2 northern provinces of Finland (99% of pregnant women in 1985-1986) | 96 | Speech, language, learning, motor abilities | NR | X | NR | NR | X | 0 | X | 0
| | | | | | | | Preterm, low birth weight | Mother | Impaired hearing | Mother's age
| | | | | | | | | | | X
| | | | | | | | | | | >4 children in family, reconstructed family status

Key/Abbreviations

X=statistically significant association

0=variable examined and not associated with delay

NR=not reported

SES=socioeconomic status

VLBW=very low birth weight

BPD=bronchopulmonary dysplasia

PDA=patent ductus arteriosis

English-language studies included case control,^39,^ ^41^–^43,^ ^45^ cross sectional,^38,^ ^40,^ ^44^ and prospective cohort^46^ designs. Sample sizes ranged from 24^38^ to 1,102^45^ subjects. Most studies evaluated risk for language delay with or without speech delay, and one restricted the evaluation to expressive language only.^46^ Family history was the most consistent significantly associated risk factor in 5 of 7 studies that examined it.^39,^ ^41,^ ^43^–^45^ Family history was defined as family members who were late talking or had language disorders, speech problems, or learning problems. Male sex was a significant factor in all 3 of the studies examining it.^39,^ ^41,^ ^44^ Three^39,^ ^43,^ ^45^ of 5 studies reported an association between lower maternal education level and language delay, while 3^43^–^45^ of 4 studies evaluating paternal education level reported a similar relationship. Other associated risk factors reported less consistently included childhood illnesses,^38,^ ^42^ born late in the family birth order,^44^ family size,^41^ older parents^41^ or younger mother^45^ at birth, and low socioeconomic status or minority race.^42^ One study evaluating history of asthma found no association with speech and language delay.^41^

The 7 studies assessing risk in non-English speaking populations include case control,^49^ cross sectional,^47^ prospective cohort,^50^–^53^ and concurrent comparison^48^ designs ranging from 72^48^ to 8,370^53^ subjects. Studies evaluated several types of delay including vocabulary,^48^ speech,^47^ stuttering,^49^ language,^50^–^53^ and learning.^51^–^53^ Significant associations were reported in the 2 studies evaluating family history,^47,^ ^50^ and one of 2 studies evaluating male sex.^53^ Three of 4 non-English language studies, including a cohort of more than 8,000 children in Finland,^53^ reported significant associations with perinatal risk factors such as prematurity,^52,^ ^53^ birth difficulties,^47^ low birth weight,^53^ and sucking habits.^47^ An association with perinatal risk factors was not found in the one English language study that examined low birth weight.^45^ Other associated risk factors reported less consistently include parental education level,^51,^ ^52^ and family factors such as size and overcrowding.^52,^ ^53^ These studies did not find associations with mother's stuttering or speaking style or rate,^49^ mother's age,^53^ and child temperament.^48^

## Key Questions 2b and 2c. What Are Screening Techniques and How Do They Differ by Age? What Is the Accuracy of Screening Techniques and How Does It Differ by Age?

A total of 44 papers reporting performance characteristics of 51 screening evaluations met inclusion criteria. Techniques taking 30 minutes or less to complete that could be administered in a primary care setting were considered to have potential for screening purposes, although many instruments were not designed specifically for this use. Studies utilized a variety of standardized and nonstandardized instruments and compared them with several different reference standards. No gold standard was acknowledged or used across studies. Instruments are described in Appendix 7. Studies were grouped by age categories according to the youngest ages included, although many studies included children in overlapping categories. Studies provided limited demographic details of subjects, and most included predominantly Caucasian children with similar proportions of boys and girls. Studies are summarized in Table 4 (up to 2 years old), Table 5 (ages 2 to 3 years), and Table 6 (ages 3 to 5 years). Quality scores are described in Appendix 8.

Table 4 Screening Instruments for Children Up To 2 Years Old

Author, Year | Instrument | Reference Standard | Area Tested | Setting | Screener | Admin. Time (minutes) | Age Mean/ Range (months) | N | Subjects | Sensitivity | Specificity | Study Quality Rating
Under 5 Minutes to Administer
Glascoe, 1991*^,^ ^67^ | Parent Evaluation of Developmental Status | Clinical assessment | Expressive language and articulation | Clinic | Doctoral students in psychology or special education | 2 | 6–77 | 157 | Subjects from an outpatient clinic or private practice | 72% | 83% | Good
| | | | | | | | | 78% Caucasian
| | | | | | | | | 54% male
Coplan, 1982*^,^ ^29^ | Early Language Milestone Scale | Clinical assessment | Expressive and receptive language | Physician's office | Medical students | 1–10 | 0–36 | 191 | Infants from private practices and pediatric outpatient department of local hospital | 97% | 93% | Fair
| | | | | | | | | 80% Caucasian
| | | | | | | | | 50% male
Black, 1988*^,^ ^63^ | Early Language Milestone Scale | Receptive-Expressive Emergent Language Scale, Bayley Scales of Infant Development | Expressive and receptive language | Large pediatric clinic, university teaching hospital | Not reported | 5 | 8–22 | 48 | Infants from low socioeconomic groups | 83% | 100% | Poor
5–10 Minutes to Administer
Glascoe, 1993*^,^ ^68^ | Developmental Profile II | Battery of measures | Fine motor adaptive, personal social, gross motor, and language | Day care centers | Psychologist | 5–10 | 7–70 | 89 | Children from five day care centers | 73% | 76% | Fair
| | | | | | | | | 52% male
Sherman, 1996^60^ | Pediatric Language Acquisition Screening Tool for Early Referral | Early Language Milestone Scale | Expressive and receptive language | High risk group: neonatal developmental follow-up clinic | Speech and language pathologist and graduate students | 5 | 3–36 | 173 | 123 high risk infants; 50 normal controls; | 53% | 86% | Fair
| | | | Control group: speech and hearing clinic | | | | | High risk: 63% African American, 37% Caucasian
| | | | | | | | | Control: 50% Caucasian
10 Minutes to Administer
Klee, 1998*^,^ ^69^ | Language Development Survey | Infant Mullen Scales of Early Learning | Expressive vocabulary | Home | Parent | 10 | 24.7 (24–26) | 306 | Toddlers turning 2-years old during the study in Wyoming | 91% | 87% | Good-Fair
| | | | | | | | | 52.2% male
Clark, 1995*^,^ ^65^ | Clinical Linguistic and Auditory Milestone Scale | Sequenced Inventory of Communication Development | Syntax and pragmatics | Home or school for the deaf | Speech and language pathologist | <10^‡^ | 0–36 | 99 | Infants turning 1 or 2 years old during study | Receptive: | Receptive: | Fair
| | | | | | | | | 55% male | 14–24 months: 83% | 14–24 months: 93%
| | | | | | | | | | 25–36 months: 68% | 25–36 months: 89%
| | | | | | | | | | Expressive: | Expressive:
| | | | | | | | | | 14–24 months: 50% | 14–24 months: 91%
| | | | | | | | | | 25–36 months: 88% | 25–36 months: 98%
Glascoe, 1993*^,^ ^68^ | Denver Developmental Screening Test II (communication components) | Battery of measures | Physical, self-help, social, academic, and communication | Day care centers | Psychologist | <10 | 7–70 | 89 | Children from five day care centers | 22% | 86% | Fair
| | | | | | | | | 52% male
Klee, 2000^54^ | Language Development Survey | Infant Mullen Scales of Early Learning | Expressive vocabulary | Home | Parent | 10 | 24 | 64 | Children turning 2 years in a specific month in an area of Wyoming | At age 2: 83% | At age 2: 97% | Fair
| | | | | | | | | | At age 3: 67 % | At age 3: 93 %
Macias, 1998^56^ | Bayley Infant Neurodevelopmental Screener | Bayley Scales of Infant Development II | Expressive and receptive language | Physician's office | Developmental pediatrician | 10 | 13 (6–23) | 78 | Infants randomly selected from those presenting for routine neonatal high-risk follow-up | Using middle-cut scores: 73% | Using middle-cut scores: 66% | Fair
| | | | | | | | | 53.8% male
| | | | | | | | | 61.5% African American
Rescorla, 2001^58^ | Language Development Survey | Bayley Scales of Infant Development, Stanford-Binet, Reynell Developmental Language Scales | Expressive vocabulary | Home | Parent and research assistant | 10 | 24 | 422 | Toddlers in four townships of Delaware County, PA turning 2-years old during the study | Delay 1: Bayley - 70%; Binet - 52%; Reynell - 67% | Delay 1: Bayley - 99%; Binet - 98%; Reynell - 94% | Fair
| | | Delay 1 = >30 words and no word combinations | | | | | | | Delay 2: Bayley - 75%; Binet - 56%; Reynell - 89% | Delay 2: Bayley - 96%; Binet - 95%; Reynell - 77%
| | | Delay 2 = >30 words or no word combinations | | | | | | | Delay 3: Bayley - 80%; Binet - 64%; Reynell - 94% | Delay 3: Bayley - 94%; Binet - 94%; Reynell - 67%
| | | Delay 3 = >50 words or no word combinations
15–30 Minutes to Administer
Leppert, 1998^55^ | Cognitive Adaptive Test/Clinical Linguistic and Auditory Milestone Scale | Bayley Scales of Infant Development II | Visual motor and language | Physician's office | Developmental pediatrician | 15–20 | 0–36 | 70 | Infants at two primary care pediatric settings presenting for well-baby visits | 44% | 97% | Fair
| | | | | | | | | 46% male
| | | | | | | | | 77% African American
| | | | | | | | | 11% premature (<38 weeks)
Borowitz, 1986*^,^ ^64^ | Denver Developmental Screening Test (DDST) (language component) | Preschool Language Scale | Expressive and receptive language and articulation | Department of pediatrics of Vanderbilt University | Psychologist | 20^‡^ | 18–66 | 71 | Infants from low income families referred to the clinic | 46% | 100% | Fair
| | | | | | | | | 82% Caucasian
| | | | | | | | | 77% male
Scherer, 1995*^,^ ^72^ | MacArthur Communicative Development Inventory: Toddler | Clinical assessment | Language | Physician's office | Pediatrician | 20 | 8–30 | 60 | Children with and without cleft palate | 76% | 91% | Fair
| | | | | | | | | 63% male
30 or More Minutes to Administer
German, 1982* | Revised Denver Developmental Screening Test (language subtest) | Sequenced Inventory of Communication Development, McCarthy's Scales of Children's General Cognitive Abilities Index, Bayley Scales of Infant Development | Expressive and receptive language | Clinic | Public health nurse | <40 | 6–68 | 84 | All children were referred to the center for delays | Expressive: 92%–96% | Expressive: 14%–49% | Good-Fair
| | | | | | | | | 58% male | Receptive: 95%–98% | Receptive: 14%–45%
| | | | | | | | | 57% Caucasian
German, 1982*^,^ ^66^ | Developmental Profile II | Sequenced Inventory of Communication Development, McCarthy's Scales of Children's General Cognitive Abilities Index, Bayley Scales of Infant Development | Expressive and receptive language | Clinic | Social worker | <40 | 6–68 | 84 | All children were referred to the center for delays | Expressive: 92%–98% | Expressive: 42%–72% | Good-Fair
| | | | | | | | | 58% male | Receptive: 93%–100% | Receptive: 36%–62%
| | | | | | | | | 57% Caucasian
Glascoe, 1993*^,^ ^68^ | Battelle Developmental Inventory Screening Test | Battery of measures | Expressive and receptive language | Day care centers | Psychologist | 30 | 7–70 | 89 | Children from five day care centers | 78% | 70% | Fair
| | | | | | | | | 52% male
Rescorla, 1989*^,^ ^71^ | Language Development Survey | Bayley Scales of Infant Development, Reynell Developmental Language Scales | Expressive vocabulary | Physician's office | Parent | 30 | 24 | 81 | Clinical and non-clinical sample | Delay 1: 53% | Delay 1: 97% | Fair
| | | Delay 1: <30 words and no combinations | | | | | | 92% male | Delay 2: 76% | Delay 2: 89%
| | | Delay 2: <30 words or no combinations | | | | | | | Delay 3: 89% | Delay 3: 86%
| | | Delay 3: <50 words or no combinations
Rescorla, 1993*^,^ ^12^ | Language Development Survey | Bayley Scales of Infant Development, Stanford-Binet | Expressive vocabulary | Home | Parent | 30 | 24 | 92 | Subjects were from one school district | Bayley: | Bayley: | Fair
| | | Delay 1: <30 words and no combinations | | | | | | | Delay 1: 78% | Delay 1: 100%
| | | Delay 2: <30 words or no combinations | | | | | | | Delay 2: 100% | Delay 2: 93%
| | | Delay 3: <50 words or no combinations | | | | | | | Delay 3: 100% | Delay 3: 90%
| | | | | | | | | | Binet: | Binet:
| | | | | | | | | | Delay 1: 67% | Delay 1: 100%
| | | | | | | | | | Delay 2: 89% | Delay 2: 93%
| | | | | | | | | | Delay 3: 100% | Delay 3: 91%
Rescorla, 2002^59^ | Language Development Survey | Child Behavior Checklist | Expressive language | Home | Parent | 30 | 18–35 | 278 | Children recruited through a national survey | 18%^†^ | 86%^†^ | Fair
| | | | | | | | | 49% male
| | | | | | | | | 57% Caucasian
Administration Time Not Reported
McGinty, 2000*^,^ ^70^ | Mayo Early Language Screening Test | Reynell Developmental Language Scales, Edinburgh Articulation Test | Expressive vocabulary | Home | Public health nurse | Not reported | 18–60 | 200 | Children referred to the speech and language therapy department in Ireland | Reynell:83.6% | Reynell: 69.9% | Poor
| | | | | | | | | Controls were added by random selection by the public health nurse at the clinics | Edinburgh: 76.5% | Edinburgh: 72.8%
Stott, 2002^61^ | General Language Screen | Reynell Developmental Language Scales, Edinburg Articulation Test, British Picture Vocabulary Scales | Expressive and receptive language | Physician's office | Parent | Not reported | Not reported | 1,861 | Infants participating in the Cambridge Language and Speech Project | 90%–100% | 31%–43.8% | Good-Fair
| | | | | | | | | 47.2% male
Ward, 1984^62^ | Author created screening tool | Receptive-Expressive Emergent Language Scale | Receptive language | Physician's office | Health visitor | Not reported | 9.7 (7–23) | 1,070 | All infants attending for their hearing tests at one clinic | 97%^†^ | 92%^†^ | Fair
Oakenfull, 2001^57^ | WILSTAAR Screen | Receptive-Expressive Emergent Language Scale | Language | Home | Speech and language pathologist | Not reported | 7 | 2,896 | Referrals from the Central Speech and Language Therapy Office | 81%^†^ | 93%^†^ | Poor

Key

* Included in Law J, Boyle J, Harris F, Harkness A, Nye C. Screening for primary speech and language delay: a systematic review of the literature. International Journal of Language & Communication Disorders. 1998;33(Suppl):21–23.

† Numbers were calculated.

‡ Numbers were estimated.

Table 5 Screening Instruments for Children 2 to 3 Years Old

Author, Year | Instrument | Reference Standard | Area tested | Setting | Screener | Admin. time (mins) | Age mean/ range (mo) | N | Subjects | Sensitivity | Specificity | Study quality rating
Under 7 minutes to administer
Burden, 1996^11^ | Parent Language Checklist | Clinical judgement | Expressive and receptive language | Home (mailed) | Parent | <5 ^‡^ | 36 | 2,590 | All children turning 36 months. | 87% | 45% | Good
| | | | | | | | | 52% male
| | | | | | | | | 41% from urban areas
Levett, 1983*^,^ ^81^ | Levett-Muir Language Screening Test | Reynell Developmental Language Scales, Goldman-Fristoe Test of Articulation, Language Assessment and Remediation Procedure | Receptive language, phonology and syntax | Physician's office | Medical practitioners | 5^‡^ | 34–40 | 140 | Private practice population. | 100% | 100% | Fair
Laing, 2002^75^ | Structured Screening Test | Reynell Developmental Language Scales | Expressive and receptive language | Physician's office | Health visitor | 5^‡^ | 30 | 376 | Children from two low SES counties in London. | Children with severe language problems: 66% | Children with severe language problems: 89% | Fair
| | | | | | | | | | Children needing therapy: 54% | Children needing therapy: 90%
Sturner, 1993*^,^ ^83^ | Fluharty Preschool Speech and Language Screening Test | Arizona Articulation Proficiency Scale Revised, Test of Language Development Primary | Expressive and receptive language and articulation | Preschool | Teacher | 5–7 | 24–72 | 279 | 46% male | Speech/Language: 43% | Speech/Language: 82% | Fair
Study 1 | | | | | | | | | 74% Caucasian | Speech: 74% | Speech: 96%
| | | | | | | | | 86% from rural areas | Language: 38% | Language: 85%
Sturner, 1993*^,^ ^83^ | Fluharty Preschool Speech and Language Screening Test | Test for Auditory Comprehension of Language Revised, Templin-Darley Test of Articulation | Expressive and receptive language and articulation | Preschool | Teacher | 5–7 | 24–72 | 421 | 52% male | Speech/Language: 31% | Speech/Language: 93% | Fair
Study 2 | | | | | | | | | 75% Caucasian | Speech: 43% | Speech: 93%
| | | | | | | | | | Language: 17% | Language: 97%
10–15 minutes to administer
Chaffee, 1990*^,^ ^78^ | Minnesota Child Development Inventory (expressive language and comprehension conceptual subscales) | Reynell Developmental Language Scales | Expressive vocabulary | Communicative disorders clinic at the Child's hospital at Chedoke-McMaster Hospital | Parent | <15^‡^ | 24–87 | 152 | Referred to clinic. | Cutoffs: | Cutoffs: | Good
| | | | | | | | | 76% male | ≤110 = 99% | ≤110 = 5%
| | | | | | | | | 97% Caucasian | ≤100 = 97% | ≤100 = 9%
| | | | | | | | | | ≤90 = 92% | ≤90 = 16%
| | | | | | | | | | ≤80 = 99% | ≤80 = 45%
| | | | | | | | | | ≤70 = 75% | ≤70 = 52%
| | | | | | | | | | ≤60 = 49% | ≤60 = 82%
| | | | | | | | | | ≤50 = 23% | ≤50 = 93%
| | | | | | | | | | ≤40 = 6% | ≤40 = 98%
Law, 1994*^,^ ^80^ | Hackney Early Language Screening Test | Reynell Developmental Language Scales | Expressive language | Home | Health visitor | 10 | 30 | 1,205 | All children attending routine developmental checkups were eligible. | 98% | 69% | Good-Fair
Blaxley, 1983*^,^ ^76^ | Fluharty Preschool Language Screening Test | Developmental Sentence Scoring | Expressive and receptive language and articulation | Speech and hearing clinic in western Ontario | Clinician | 10 | 24–72 | 90 | Children referred for speech &/or language assessment and intervention and controls. | 10th centile: 36% | 10th centile: 95% | Fair
| | | | | | | | | | 25th centile: 30% | 25th centile: 100%
Bliss, 1984*^,^ ^77^ | Screening Kit of Language Development | Sequenced Inventory of Communication Development | Expressive and receptive language | Speech and language hearing clinic, day-care center, physician's office, educational and health facilities | Paraprofessionals and speech and language pathologists | 10 | 30–48 | 602 | 2.5–4 year old Caucasian and African American children who attended day-care centers in metropolitan Detroit area. | Standard English | Standard English | Fair
| | | | | | | | | | Ages 30–36 mo.: 100% | Ages 30–36 mo.: 97.7%
| | | | | | | | | | Ages 37–42 mo.: 100% | Ages 37–42 mo.: 91.0%
| | | | | | | | | | Ages 43–48 mo.: 100% | Ages 43–48 mo.: 93.4%
| | | | | | | | | | “Black English” | “Black English”
| | | | | | | | | | Ages 30–36 mo.: 88.9% | Ages 30–36 mo.: 86.4%
| | | | | | | | | | Ages 37–42 mo.: 87.5% | Ages 37–42 mo.: 85.5%
| | | | | | | | | | Ages 43–48 mo.: 94.4% | Ages 43–48 mo.: 77.8%
Drumwright, 1973^74^ | Denver Articulation Screening Exam | Templin Non-Diagnostic Articulation Screening Test | Articulation | Clinic | Trained non-professionals | 10–15 | 30–72 | 300 | Not reported | 92% | 97% | Fair
Dixon, 1988*^,^ ^79^ | Hackney Early Language Screening Test | Clinical judgement | Expressive language | Physician's office | Health visitor | 10 | 30 | 25 | Pilot study at one clinic setting in Hackney. | 95% | 94% | Poor
Walker, 1989*^,^ ^84^ | Early Language Milestone Scale | Sequenced Inventory of Communication Development | Expressive and receptive language | Clinic | Speech and language pathologist | 10 | 36 | 77 | All children attending any visit at one of the clinics chosen during the study period. | 0–12 months: 0% | 0–12 months: 86% | Poor
| | | | | | | | | | 13–24 months: 100% | 13–24 months: 60%
| | | | | | | | | | 25–36 months: 100% | 25–36 months: 75%
10–30 minutes to administer
Laing, 2002^75^ | Parent Led Method | Reynell Developmental Language Scales | Language development | Physician's office | Health visitor | 10–30^‡^ | 30 | 247 | Children from two low SES counties in London. | Children with severe language problems: 56% | Children with severe language problems: 85% | Fair
| | | | | | | | | | Children needing therapy: 58% | Children needing therapy: 90%
Administration time not reported
Stokes, 1997*^,^ ^82^ | Developmental Nurse Screen | Clinical judgement | Gross & fine motor, language development, hearing, vision, social development & self-help | Physician's office | Nurses | Not reported | 34–40 | 398 | 49% male | 76% | 97% | Fair
Stokes, 1997*^,^ ^82^ | Parent Questionnaire | Clinical judgment | Expressive vocabulary | Physician's office | Research assistants | Not reported | 34–40 | 398 | 49% male | With comprehension item: 78% | With comprehension item: 91% | Fair
| | | | | | | | | | Without comprehension item: 78% | Without comprehension item: 95%

Key

* Included in Law J, Boyle J, Harris F, Harkness A, Nye C. Screening for primary speech and language delay: a systematic review of the literature. Int J Lang Commun Disord. 1998;33(Suppl):21–23.

† Numbers were calculated

‡ Numbers were estimated

Table 6 Screening Instruments for Children 3 to 5 Years

Author, Year | Instrument | Reference Standard | Area Tested | Setting | Screener | Admin. Time (minutes) | Age Mean/ Range (months) | N | Subjects | Sensitivity | Specificity | Study Quality Rating
Under 7 Minutes to Administer
Merrell, 1997^88^ | Test for Examining Expressive Morphology | Kaufman Assessment Battery for Children, Structured Photographic Expression Language Test II | Expressive vocabulary and syntax | School or clinic | Speech and language pathologists | 7 | 48–67 | 40 | 20 impaired and 20 normal children | 90% | 95% | Poor
| | | | | | | | | 52% male
| | | | | | | | | 73% Caucasian
Sturner, 1996*^,93^ | Sentence Repetition Screening Test | Speech and Language Screening Questionnaire | Receptive and expressive language and articulation | School | College-educated non-specialists or school speech and language pathologists | 3 | 54–66 | 76 | Children registering for kindergarten | Receptive and expressive: 62% | Receptive and expressive: 91% | Fair
| | | | | | | | | 48% male | Articulation: 57% | Articulation: 95%
| | | | | | | | | 65% Caucasian
10–20 Minutes to Administer
Alberts, 1995^85^ | Davis Observation Checklist for Texas | McCarthy Scales of Children's Abilities, Goldman-Fristoe test of Articulation Revised, informal checklist | Speech, voice, fluency, receptive and expressive language | Preschool | Teachers and aides | 10–15 | 52–67 | 59 | Preschool, Headstart children | 80% | 90% | Good
| | | | | | | | | 20 Mexican American
| | | | | | | | | 19 African American
| | | | | | | | | 20 Caucasian
Gray, 2003^87^ | Children's Test of Nonword Repetition | Structured Photographic Expression Language Test II | Expressive language | School | Research assistants | 15 | 48–72 | 44 | 22 children with impairment and 22 controls matched for age and gender. Children were between 4 years and 5 years 11 months old | 95% | 100% | Poor
| | | | | | | | | 72% Caucasian
| | | | | | | | | 77% male
Allen, 1987*^,73^ | Fluharty Preschool Speech and Language Screening Test | Sequenced Inventory of Communication Development | Expressive and receptive language and articulation | Clinic | Speech and language pathologists | 10–20 | 36–47 | 182 | All children were enrolled in day care programs | 60% | 80% | Fair
Plante, 1995^89^ | Structured Photographic Expressive Language Test - Preschool | Kaufman Assessment Battery for Children, Structured Photographic Expression Lanuage Test II | Expressive vocabulary | School | Speech and language pathologists or research assistants | 15 | 48–72 | 40 | 75% Caucasian | 83.3% | 95% | Poor
Conti-Ramsden, 2003^86^ | Children's Test of Nonword Repetition | Clinical judgement | Phonology | School/Nursery | Not reported | 15 | 52–70 | 64 | 66% male | 25th centile: 66% | 25th centile: 100% | Fair
| | | | | | | | | | 16th centile: 59% | 16th centile: 100%
Feeney, 1996*^,92^ | Revised Denver Developmental Screening Test (language component) | Clinical judgement | Language | School | Speech and language pathology students | 10–20 | 36–60 | 199 | Children in Head Start program | 95% | 80% | Fair
| | | | | | | | | 45% male
| | | | | | | | | 67% Caucasian
Wilcox, 1998^90^ | Wilcox African-American English Screening Test of Articulation | Clinical judgement | Articulation and phonology | School | Investigators | 15 | 60–78 | 26 | Children enrolled in kindergarten or first grade classrooms in Indianapolis, IN | 100% | 100% | Poor
| | | | | | | | | Mean age: 68 months
| | | | | | | | | 77% male
Allen, 1987*^73^ | Northwestern Syntax Screening Test | Sequenced Inventory of Communication Development | Syntax | Clinic | Speech and Language Pathologists | 20 | 36–47 | 182 | All children were enrolled in day care programs | 92% | 48% | Fair
Dodge, 1980*,^91^ | Denver Developmental Screening Test | Clinical assessment | Expressive and receptive language and articulation | School | Speech clinician | 20 | 60 | 486 | Children entering kindergarten, who were 5 years or turning 5 that year | 97% | 98% | Fair-Poor
25–30 Minutes to Administer
Blaxley, 1983^76^ | Bankson Language Screening Test | Developmental Sentence Scoring | Expressive language | Speech and hearing clinic in western Ontario, Canada | Clinician | 25 | 48–96 | 90 | Children referred for speech and/or language assessment and intervention and controls | 10th centile: 64% | 10th centile: 91% | Fair
| | | | | | | | | | 25th centile: 63% | 25th centile: 94%

Key

* Included in Law J, Boyle J, Harris F, Harkness A, Nye C. Screening for primary speech and language delay: a systematic review of the literature. Int J Lang Commun Disord. 1998;33(Suppl):21–23.

† Numbers were calculated.

‡ Numbers were estimated.

Ages 0 to 2 years. Twenty-one studies described performance characteristics of 25 evaluations for children up to 2 years old.^12,^ ^29,^ ^54^–^72^ Eleven studies from 10 publications utilized instruments taking 10 minutes or less to administer, including the Early Language Milestone Scale,^29,^ ^63^ Parent Evaluation of Developmental Status,^67^ Denver Developmental Screening Test II (language component),^68^ Pediatric Language Acquisition Screening Tool for Early Referral,^60^ Clinical Linguistic and Auditory Milestone Scale,^65^ Language Development Survey,^54,^ ^58,^ ^69^ and the Bayley Infant Neurodevelopmental Screener.^56^ Of these, 6 studies tested expressive and/or receptive language,^29,^ ^56,^ ^60,^ ^63,^ ^67,^ ^68^ 3 expressive vocabulary,^54,^ ^58,^ ^69^ one articulation,^73^ and one syntax and pragmatics.^65^ Testing was conducted in general health clinics, specialty clinics, day care centers, schools, and homes by pediatricians, speech and language specialists, psychologists, medical or graduate students, parents, and research assistants. Study sizes ranged from 48^63^ to 422^58^ subjects. One study enrolled predominantly African American children.^60^

For the 10 fair and good-quality studies providing data to determine sensitivity and specificity of evaluating children up to 2 years old with instruments administered in 10 minutes or less sensitivity ranged from 22% to 97% and specificity from 66% to 97% (Figure 3a–b).^29,^ ^54,^ ^56,^ ^58,^ ^60,^ ^65,^ ^67^–^69^ Four studies reported sensitivity and specificity of 80% or better: a fair-quality study using the Early Language Milestone Scale,^29^ 2 studies, rated fair to good^69^ and fair,^54^ using the Language Development Survey, and one fair-quality study using the Clinical Linguistic and Auditory Milestone Scale.^65^ The study of the Clinical Linguistic and Auditory Milestone Scale also determined sensitivity and specificity by age, and reported higher sensitivity/specificity at age 14 to 24 months (83%/93%) than 25 to 36 months (68%/89%) for receptive function, but lower sensitivity/specificity at age 14 to 24 months (50%/91%) than 25 to 36 months (88%/98%) for expressive function.^65^ A study testing expressive vocabulary using the Language Development Survey indicated higher sensitivity/specificity at age 2 years (83%/97%) than at age 3 years (67%/93%).^54^

Figure 3A. Sensitivity and Specificity of Instruments for Ages up to 2 years

Studies rated fair to good with instruments taking 10 minutes or less time to administer

Figure 3B. References for Figure 3A

Ages 2 to 3 years. Twelve studies described performance characteristics of 14 evaluations for children ages 2 to 3 years.^11,^ ^74^–^84^ Ten studies in 9 publications utilized instruments taking 10 minutes or less to administer, including the Parent Language Checklist,^11^ Structured Screening Test,^75^ Levett-Muir Language Screening Test,^81^ Fluharty Preschool Speech and Language Screening Test,^76,^ ^83^ Screening Kit of Language Development,^77^ Hackney Early Language Screening Test,^79,^ ^80^ and Early Language Milestone Scale.^84^ All studies tested expressive and/or receptive language,^11,^ ^75^–^77,^ ^79^–^81,^ ^83,^ ^84^ 3 articulation,^76,^ ^83^ and one syntax and phonology.^81^ Testing was conducted in general health clinics, specialty clinics, preschools, and homes by pediatricians, speech and language specialists, teachers, parents, and health visitors. Study sizes ranged from 25^79^ to 2,590^11^ subjects. One study included subjects predominantly from rural areas.^83^

For the 8 fair and good quality studies providing data to determine sensitivity and specificity of evaluating children ages 2 to 3 years with instruments administered in 10 minutes or less, sensitivity ranged from 17% to 100% and specificity from 45% to 100% (Figure 4a–b). Two studies reported sensitivity and specificity of 80% or better: one study rated fair that used the Levett-Muir Language Screening Test,^81^ and one rated fair that used the Screening Kit of Language Development.^77^ The study of the Screening Kit of Language Development reported comparable sensitivity/specificity at ages 30 to 36 months (100%/98%), 37 to 42 months (100%/91%), and 43 to 48 months (100%/93%).^77^

Figure 4A. Sensitivity and Specificity of Instruments for Ages 2 to 3 Years

Studies rated fair to good with instruments taking 10 minutes or less time to administer

Figure 4B. References for Figure 4A

Ages 3 to 5 years. Eleven studies described performance characteristics of 12 evaluations for children ages 3 to 5 years.^73,^ ^76,^ ^85^–^93^ Three studies utilized instruments taking 10 minutes or less to administer, including the Fluharty Preschool Speech and Language Screening Test,^73^ Test for Examining Expressive Morphology,^88^ and the Sentence Repetition Screening Test.^93^ Of these, 2 studies tested expressive and receptive language and articulation,^73,^ ^93^ and one expressive vocabulary and syntax.^88^ Testing was conducted in general clinics, specialty clinics, and preschools by nurses, speech and language specialists, and teachers. Study sizes ranged from 40^88^ to 182^73^ subjects.

For the 3 fair quality studies providing data to determine sensitivity and specificity of evaluating children ages 3 to 5 years with instruments administered in 10 minutes or less (including the study of the Screening Kit of Language Development described in the previous section^77^), sensitivity ranged from 57% to 100% and specificity from 80% to 95% (Figure 5a–b).^73,^ ^77,^ ^93^

Figure 5A. Sensitivity and Specificity of Instruments for Ages 3 to 5 years

Studies rated fair to good with instruments taking 10 minutes or less time to administer

Figure 5B. References for Figure 5A

Systematic review. A Cochrane systematic review of 45 studies, including most of the studies cited above, summarized the sensitivity and specificity of instruments taking 30 minutes or less to administer.^9^ Sensitivity of instruments for normally developing children ranged from 17% to 100%, and for children from clinical settings from 30% to 100%. Specificity ranged from 43% to 100%, and 14% to 100% respectively. Studies considered to be of higher quality tended to have higher specificity than sensitivity (+=4.41, p<0.001), however, high false-positive and false-negative rates were often reported.^9^

## 2d. What Are the Optimal Ages and Frequency for Screening?

No studies addressed this question.

## Key Question 3. What Are the Adverse Effects of Screening?

No studies addressed this question. Potential adverse effects include false positive and false negative results. False positive results can erroneously label children with normal speech and language as impaired, potentially leading to anxiety for children and families and further testing and interventions. False negative results would miss identifying children with impairment, potentially leading to progressive speech and language delay and other long-term effects including communication, social, and academic problems. In addition, once delay is identified, children may be unable to access services because of unavailability or lack of insurance coverage.

## Key Question 4. What Is the Role of Enhanced Surveillance by Primary Care Clinicians?

This question relates to the role of enhanced surveillance by a primary care clinician once a child demonstrates clinical concern for speech and language delay. No studies addressed this question.

## Key Question 5. Do Interventions for Speech and Language Delay Improve Speech and Language Outcomes?

Twenty-five randomized controlled trials in 24 publications met inclusion criteria (Table 7; Appendix 9) including one rated good,^94^ 13 fair,^95^–^107^ and 11 poor quality^99,^ ^108^–^117^ (Appendix 10). Studies were considered poor quality if they reported important differences between intervention and comparison groups at baseline, did not use intention-to-treat analysis, no method of randomization was reported, and there were fewer than 10 subjects in intervention or comparison groups. Limitations of studies, in general, include small numbers of participants (only 4 studies enrolled more than 50 subjects), lack of consideration of potential confounders, and disparate methods of assessment, intervention, and outcome measurement. As a result, conclusions about effectiveness are limited. Although children in the studies ranged from 18 to 75 months old, most studies included children age 2 to 4 years old and results do not allow determination of optimal ages of intervention.

Table 7 Summary of Randomized Controlled Trials of Interventions

Author, Year | Speech & Language Domains | N | Age (months) | Interventions | Speech and Language Outcomes | Function and Health Outcomes | Study Quality Rating
Up to 2 Years*
Glogowska, 2000^94^ | Expressive and receptive language and phonology | 159 in 2 groups | 18–42 | Clinician-directed individual intervention routinely offered by the therapist for 12 months vs. none | Improved auditory comprehension in intervention vs. control group; no differences for expressive language, phonology error rate, language development, or improvement on entry criterion | No differences in well being, attention level, play level, or socialization skills | Good
2 to 3 Years
Gibbard, 1994^99^ | Expressive language | 36 in 2 groups | 27–39 | Parent-directed individual therapy 60–75 minutes every other week for 6 months vs. none | Improved scores on several measures for intervention vs. control group | Not reported | Fair
Study 1
Girolametto, 1996^100^ | Expressive language | 25 in 2 groups | 23–33 | Parent-directed individual focused stimulation intervention 150 minutes per week for 11 weeks vs. none | Larger vocabularies, use of more different words, more structurally complete utterances and multiword utterances in intervention group vs. control; no differences in several other measures | Not reported | Fair
Law, 1999^107^ | Expressive and receptive language | 38 in 3 groups | 33–39 | Clinician-directed 450 minutes per week for 6 weeks vs. parent-directed 150 minutes per week for 10 weeks vs. none | No differences between groups | Improved parent perception of child's behavior and positivity towards child, improved child self-esteem | Fair
Robertson, 1999^102^ | Expressive and receptive language | 21 in 2 groups | 21–30 | Clinician-directed individual therapy 150 minutes per week for 12 weeks vs. none | Improved mean length of utterances, total number of words, lexical diversity, vocabulary size, and percentage of intelligible utterances in intervention group vs. control | Improved socialization skills, decreased parental stress for intervention group | Fair
Gibbard, 1994 | Expressive language | 25 in 3 groups | 27–39 | Clinician-directed individual therapy 60–75 minutes every other week for 6 months vs. parent-directed 60–75 minutes every other week for 6 months vs. none | Improved scores on all 5 measures for parent-directed group vs. control; improvement on 2 measures for clinician-directed group vs. control; improvement on 1 measure for parent vs. clinician group | Not reported | Poor
Study 2
Girolametto, 1996^115^ | Expressive and receptive language | 16 in 2 groups | 22–38 | Parent-directed individual therapy 150 minutes per week for 10 weeks vs. none | More target words used in intervention group vs. control; no differences in vocabulary development | Increased symbolic play gestures, decreased aggressive behavior in intervention group | Poor
Schwartz, 1985^113^ | Expressive language and lexical acquisition | 10 in 2 groups | 32–39 | Clinician-directed individual therapy for 3 weeks vs. none | Improved multiword utterances from baseline in intervention group; no between-group differences reported | Not reported | Poor
Wilcox, 1991^106^ | Lexical acquisition | 20 in 2 groups | 20–47 | Clinician-directed individual intervention 90 minutes per week for 3 months vs. classroom intervention 360 minutes per week for 3 months | No differences between groups in use of target words; more use of words at home in classroom group vs. individual group | Not reported | Fair
Girolametto, 1997^101^ | Lexical acquisition and phonology | 25 in 2 groups | 23–33 | Parent-directed individual therapy eight 150-minute sessions and 3 home sessions for 11 weeks vs. none | Improved level of vocalizations and inventory of consonants for intervention group vs. control; no differences in the number of vocalizations | Not reported | Fair
3 to 5 Years
Barratt, 1992^96^ | Expressive and receptive language | 39 in 2 groups | 37–43 | Clinician-directed interactive language therapy for 40 minutes weekly for 6 months (traditional group) vs. 40 minutes for 4 days per week for 3 weeks in two 3 month blocks (intensive group) | Improved expression score on Reynell scale for intensive group vs. weekly (or traditional) therapy group; no difference in comprehension scores, both improved | Not reported | Fair
Courtright, 1979^98^ | Expressive language | 36 in 3 groups | 47–83 | 3 clinician-directed approaches are compared for 5 months: mimicry, clinician modeling, 3rd person modeling for 5 months | Increased number of correct responses in modeling groups vs. mimicry group | Not reported | Fair
Robertson, 1997^103^ | Expressive and receptive language | 30 in 3 groups | 44–61 | 2 clinician-directed play groups with language impairments (treatment vs control) with normal peers for 20 minutes per week for 3 weeks | More words used, greater verbal productivity, more lexical diversity, and more use of linguistic markers by normal peer play group (not normal group, treatment group with language impairment) vs. control | Play-theme-related acts increased for the normal peer play group (not normal group, treatment group with language impairment) | Fair
Glogowska, 2002^116^ | Expressive and receptive language and phonology | 159 in 2 groups | ≤42 | Clinician-directed for 12 months vs. none | Improved receptive language in intervention group vs. control; no differences between groups for 4 other measures | Improved family response to child in intervention group | Poor
Almost, 1998^95^ | Phonology | 26 in 2 groups | 33–61 | Clinician-directed individual therapy two 30-minute sessions per week for 4 months vs. none | Higher scores on 3 of 4 measures for intervention vs. control group | Not reported | Fair
Rvachew, 2001^104^ | Phonology | 48 in 2 groups | 50 (mean) | Clinician-directed individual therapy 30–40 minutes per week for 12 weeks; compares interventions for phonemes that differ (most knowledge/early developing group vs. least knowledge/latest developing group) | Improved scores on measures from baseline for both intervention groups; greater improvement for most knowledge/early developing phonemes group vs. comparison (least knowledge/latest developing) group | Not reported | Fair
Shelton, 1978^105^ | Phonology and articulation | 45 in 3 groups | 27–55 | Parent-directed individual therapy 5 minutes per day (listening group) vs. 15 minutes per day (reading and talking group) for 57 days vs. none | No improvements for intervention groups vs. control | Not reported | Fair
Fey, 1994^108^ | Phonology and syntax | 26 in 3 groups | 44–70 | Clinician-directed sessions (individual and group) for 3 hours per week for 20 weeks vs. parent-directed sessions for 8 hours per week for weeks 1–12 (includes intensive parent training) then 4 hours per week for weeks 13–20 vs. none | Improved grammatical output (developmental sentence scores) for both intervention groups vs. control; no significant difference between groups for phonological output (percentage consonants correct) | Not reported | Poor
Reid, 1996^117^ | Phonology | 30 in 2 groups | 42–66 | Clinician-directed individual therapy 30 minutes per week for 6–10 weeks vs. none | Improved scores on some measures from baseline for intervention and control groups; no between group comparisons reported | Not reported | Poor
Ruscello, 1993^111^ | Phonology | 12 in 2 groups | 49–68 | Clinician-directed vs. clinician & parent-directed individual therapy 120 minutes per week for 8 weeks | Improved scores on measures from baseline for both intervention groups; no between group comparisons reported | Not reported | Poor
Rvachew, 1994^112^ | Phonology | 27 in 3 groups | 42–66 | Clinician-directed individual therapy 45 minutes per week for 6 weeks; compares 3 groups listening to different sets of words | Improved scores on measures for 2 intervention groups vs. third group | Not reported | Poor
Cole, 1986^97^ | Syntax | 44 in 2 groups | 38–69 | Clinician-directed individual directive approach vs. interactive approach for 600 minutes per week for 8 months | Improved scores on 6 of 7 measures from baseline for both intervention groups; no significant differences between groups | Not reported | Fair
Fey, 1993^114^ | Syntax | 29 in 3 groups | 44–70 | Clinician-directed sessions (individual and group) for 3 hours per week for 20 weeks vs. parent-directed sessions for 8 hours per week for weeks 1–12 (includes intensive parent training) then 4 hours per week for weeks 13–20 vs. none | Improved scores on 3 of 4 measures for both intervention groups vs. control; no differences between intervention groups | Not reported | Poor
First phase
Fey, 1997^109^ | Syntax | 28 in 3 groups | 44–70 | Clinician-directed vs. parent-directed vs. none for 5 months continuing from prior study | Improved some developmental sentence scores from baseline in both intervention groups vs. control; no between group comparisons reported, except that clinician-directed treatment groups had larger and more consistent gains than parent-directed treatment groups or control | Not reported | Poor
Second phase
Mulac, 1977^110^ | Syntax | 9 in 3 groups | 52–75 | Clinician-directed individual Monteray language program vs. Monteray language program with extended transfer training for 67 minutes per week for 4 weeks vs. none | Improved scores for both intervention groups vs. control; no significant differences between intervention groups | Not reported | Poor

Key

* Studies with a range of ages are not repeated across categories in the table.

Studies evaluated the effects of individual or group therapy directed by clinicians and/or parents focusing on specific speech and lanugage domains. These include expressive and receptive language, articulation, phonology, lexical acquisition, and syntax. Several studies used established approaches to therapy, such as the WILSTAAR program^118^ and the HANEN principles.^100,^ ^101,^ ^107,^ ^115^ Others used more theoretical approaches, such as focused stimulation,^100,^ ^101,^ ^108,^ ^109,^ ^115^ auditory discrimination,^105,^ ^112^ imitation or modeling procedures,^98,^ ^114^ auditory processing or work mapping,^107^ and play narrative language.^102,^ ^103^ Some interventions focused on specific words and sounds, used unconventional methods, or targeted a specific deficit.

Outcomes were measured by subjective reports from parents,^99,^ ^100,^ ^102,^ ^107^ and by scores on standardized instruments, such as the Reynell Expressive and Receptive Scales,^96,^ ^99^ the Preschool Language Scale,^94,^ ^97,^ ^107^ and the MacArthur Communicative Development Inventories.^102,^ ^115^ The most widely used outcome measure was Mean Length Utterances (MLUs) used by 6 studies.^95,^ ^97,^ ^99,^ ^102,^ ^107^

Studies rated good or fair quality are described below by age categories according to the youngest ages included, although many studies included children in overlapping categories.

Ages 0 to 2 years. No studies examined this age group exclusively, although one good-quality study enrolled children 18 to 42 months old.^94^ The clinician-directed, 12-month intervention consisted of 10-minute weekly sessions focusing on multiple language domains, expressive and receptive language, and phonology. Treatment for receptive auditory comprehension lead to significant improvement for the intervention group compared to control group, however, results did not differ between groups for several expressive and phonology outcomes.^94^

Ages 2 to 3 years. One good^94^ and 6 fair-quality studies^99^–^102,^ ^106,^ ^107^ evaluated speech and language interventions for children 2 to 3 years old. Studies reported improvement on a variety of communication domains including clinician-directed treatment for expressive and receptive language,^102^ parent-directed therapy for expressive delay,^99,^ ^100^ and clinician-directed receptive auditory comprehension.^94^ Lexical acquisition was improved with both clinician-directed therapy^106,^ ^113^ and group therapy approaches.^106^ In 3 studies, there were no between group differences for clinician-directed expressive^94,^ ^107^ or receptive language therapy,^94,^ ^107^ parent-directed expressive or receptive therapy,^107^ or parent-directed phonology treatment.^101^

Ages 3 to 5 years. Five fair-quality studies reported significant improvements for children 3 to 5 years old undergoing interventions compared to controls,^95,^ ^96,^ ^98,^ ^103,^ ^104^ while 2 studies reported no differences.^97,^ ^105^ Both group-based interventions^103^ and clinician-directed interventions^96^ were successful at improving expressive and receptive competencies.

Systematic review. A Cochrane systematic review included a meta-analysis utilizing data from 25 randomized controlled trials of interventions for speech and language delay for children up to adolesence.^36^ Twenty-three of these studies also met criteria for this review and were included,^94^–^114,^ ^117^ and 2 trials were unpublished. The review reported results in terms of standard mean differences (SMD) in scores for a number of domains (expressive and receptive phonology, syntax, and vocabulary). Effectiveness was considered significant for both the phonological (SMD=0.44; 95% CI, 0.01–0.86) and vocabulary (SMD=0.89; 95% CI, 0.21–1.56) interventions. Less effective was the receptive intervention (SMD=-0.04; 95% CI, 0.64-0.56), and results were mixed for the expressive syntax intervention (SMD=1.02; 95% CI, 0.04–2.01). In the analysis, when interventions were comparable in duration and intensity, there were no differences between interventions when administered by trained parents or clinicians for expressive delays. Use of normal language peers as part of the intervention strategy also proved beneficial.^103^

## Key Question 6. Do Interventions for Speech and Language Delay Improve Other Non-Speech and Language Outcomes?

Four good^94^ or fair-quality^102,^ ^103,^ ^107^ intervention studies included functional outcomes other than speech and language (Table 7; Appendix 9). Increased toddler socialization skills,^102^ improved child self-esteem,^107^ and improved play themes^103^ were reported for children in intervention groups in 3 studies. Improved parent-related functional outcomes included decreased stress^102^ and increased positive feelings toward their children.^107^ Functional outcomes studied but not showing significant treatment effects included well being, levels of play and attention, and socialization skills in one study.^94^

## Key Question 7. Does Improvement in Speech and Language Outcomes Lead to Improved Additional Outcomes?

No studies addressed this question.

## Key Question 8. What Are the Adverse Effects of Interventions?

No studies addressed this question. Potential adverse effects of treatment programs include the impact of time and cost of interventions on clinicians, parents, children, and siblings. In addition, loss of time for play and family activities, stigmatization, and labeling may be potential adverse effects.

## Key Question 9. What Are Cost-Effectiveness Issues?

No studies addressed this question.