# Methods

## Literature Search and Strategy

Relevant studies were identified from multiple searches of MEDLINE, PsycINFO, and CINAHL databases (1966 to November 19, 2004). Search strategies are described in Appendix 2. Additional articles were obtained from recent systematic reviews,^9,^ ^36^ reference lists of pertinent studies, reviews, editorials, and websites, and by consulting experts. In addition, investigators attempted to collect instruments and accompanying manuals, however, these materials are not generally available and must be purchased limiting the evidence review to published papers available through libraries.

## Inclusion/Exclusion Criteria

Investigators reviewed all abstracts identified by the searches and determined eligibility by applying inclusion and exclusion criteria specific to each key question (Appendix 3). Full-text articles of included abstracts were then reviewed for relevance. Eligible articles had English-language abstracts, were applicable to U.S. clinical practice, and provided primary data relevant to key questions. Studies of children with previously diagnosed conditions known to cause speech and language delay (e.g., autism, mental retardation, Fragile X, hearing loss, degenerative and other neurological disorders) were not included because the scope of this review is screening children without known diagnoses. Only randomized controlled trials were considered for examining the effectiveness of interventions. Studies related to other key questions included controlled trials, observational studies, and systematic reviews.

Studies of risk factors were included if they focused on children 5 years or younger, reported associations between predictor variables and speech and language outcomes, and were relevant to selecting candidates for screening. Otitis media as a risk factor for speech and language delay is a complex and controversial area and was not included in this review.

Studies of techniques to assess speech and language were included if they focused on children age 5 years and younger, could be applied to a primary care setting, used clearly defined measures, compared the screening technique to an acceptable reference standard, and reported data allowing calculation of sensitivity and specificity. Techniques taking more than 30 minutes to administer or could only be administered by specialists were considered inappropriate for routine screening in primary care. In general, if the instrument was administered by primary care physicians, nurses, research associates, or other nonspecialists for the study, it was assumed that it could be administered by nonspecialists in a clinic. For questionable cases, experts in the field were consulted to help determine appropriateness for primary care. Broader developmental screening instruments were included, such as the Ages and Stages Questionnaire and Denver Developmental Screening Test, if they provided outcomes related to speech and language delay specifically.

Outcome measures were considered if they were obtained at any time or age after screening and/or intervention as long as the initial assessment occurred while the child was age 5 years or younger. Outcomes included speech and language measures as well as other functional (e.g., social behavior, self-esteem, peer interaction and school performance) and health outcomes.

## Data Extraction and Synthesis

All eligible studies were reviewed, and data were extracted from each study, entered into evidence tables, and summarized by descriptive methods. For some studies of screening instruments, sensitivity and specificity were calculated by the investigators if adequate data were presented in the paper. No statistical analyses were performed because of heterogeneity of studies, and investigators and members of the USPSTF concluded that speech and language outcomes do not provide data appropriate for an outcomes table model. Investigators independently rated the quality of studies using criteria specific to different study designs developed by the USPSTF (Appendix 4).^37^ The quality of the study does not necessarily indicate the quality of an instrument or intervention, but may influence interpretation of the results of the study.

## Size of Literature Reviewed

Investigators reviewed 5,377 abstracts identified by the searches (Appendix 5), and excluded 4,687 articles from further review because they focused on animals, studied the wrong population, were not applicable to U.S. clinical practice, were an opinion or letter with no data, or did not address key questions. From the searches, 690 full-text articles were reviewed. An additional 55 non-duplicate articles identified from reference lists and experts were also reviewed.

Appendix 5. Search And Selection Of Literature