# Appendix 10. Quality Ratings of Intervention Studies

Study | Randomization | Blinding of Assessors | Similarities at Baseline | Explanation of Withdrawals | Discounting in Analysis of Missing Values | Degree of Attrition | Intention to Treat Analysis | Power | Description of Eligibility Criteria | USPSTF Quality Rating
Almost, 1998*^, †^ | A | A | A | A | A (last known scores used) | C (.15) | A (I to T) | A | A | Fair
Barratt, 1992* | B | B | B | A | C | A (.07) | B | A | A | Fair
Cole, 1986* | B | B | A | B | B | B | B | B | A | Fair
Courtright, 1979* | B | A | B | B | B | B | B | B | B | Fair
Fey, 1993*^, †^ | B | A | C (mother's education) | A | C | A (.03) | B | B | A | Poor
Fey, 1994* | B | C | A | A | A (none) | A (none) | B | B | A | Poor
Fey, 1997* | B | A | A | A | C | A (.06) | B | B | A | Poor
Gibbard, 1994* | B | B | A | A (none) | A (none) | A (none) | B | B | A | Poor
Study 2
Gibbard, 1994*^, †^ | B | B | A | A (none) | A (none) | A (none) | B | B | A | Fair
Study 1
Girolametto, 1996*^, †^ b | B | A | A | A (none) | A (none) | A (none) | B | B | A | Fair
Girolametto, 1996^†^a | B | A | C (behavior) | A (none) | A (none) | A (none) | B | B | A | Poor
Girolametto, 1997* | B | A | A | A (none) | A (none) | A (none) | B | B | A | Fair
Glogowska, 2000* | A | A | A | A | C | A (.03) | A (I to T) | C | A | Good
Glogowska, 2002 | A | B | B | C | B | B | B | B | C | Poor
Law, 1999^†^ | A | A | C (esteem, behaviour) | A | C | C (.12) | B | C | A | Fair
Mulac, 1977* | B | A | B | B | B | B | B | B | B | Poor
Reid, 1996*^, †^ | B | B | C (medians) | A (subgroup) | A (subgroup) | A (subgroup) | B | B | A | Poor
Robertson, 1997 | A | B | A | A | B | A (none) | B | B | A | Fair
Robertson, 1999* | B | B | A | A | C | C (.13) | B | B | A | Fair
Ruscello, 1993* | B | B | A | B | B | B | B | B | A | Poor
Rvachew, 1994* | B | A | A | B | C | C (.13) | B | B | A | Poor
Rvachew, 2001* | B | A | A | A | B | B | B | B | A | Fair
Schwartz, 1985*^, †^ | B | C | B | B | B | B | B | B | A | Poor
Shelton, 1978*^, †^ | B | B | A | A | C | A (.08) | B | B | A | Fair
Wilcox, 1991* | B | B | A | B | B | B | B | B | A | Fair

Key

* Law J, Garrett Z, Nye C. Speech and language therapy interventions for children with primary speech and language delay or disorder. Cochrane Database of Syst Rev. 2003(3):CD004110.

† Law J, Boyle J, Harris F, Harkness A, Nye C. Screening for primary speech and language delay: a systematic review of the literature. Int J Lang Commun Disord. 1998;33(Suppl):21–23.