# Appendix 9. Evidence Table: Randomized Controlled Trials of Interventions

Author, Year Title | Objectives | Area of Intervention | Setting | N | Subjects | Screening Criteria/Diagnostic Evaluation | Time from Screen to Intervention | Interventions | Length of Intervention | Outcome Measures | Speech and Lanuage Outcomes | Non Speech and Language Outcomes
Almost, 1998*^, †^ | To examine effectiveness of treatment for children with severe phonological disorders as typically seen in an ambulatory care speech-language-pathology clinic in a community hospital | Phonology | Speech and language pathology department clinic in a community hospital in SW Ontario, Canada | 26 | Group 1: mean age 42.5 months (33–61) | Severe phonological disorder as determined by the phonological deviancy score on the Assessment of Phonological Processes - Revised (AAP-R) | Group 1: immediate treatment implied | Group 1: 4 months treatment followed by 4 months no treatment. Group 2: 4 months no treatment followed by 4 months treatment. Assessments at baseline, 4, and 8 months. Treatment: remediation for phonological disorders. Individual 30 minute sessions 2× per week. 4 – 6 target phonological deviations chosen for each child at treatment cycle initiation. Each target repeated 2 – 3 times or until correct in conversation | 4 months | APP-R (Assessment of Phonological Processes-Revised) score | 4 month assessment: Group 1- scores of phonological measures reflect improvement: APP-R (p=0.05), GFTA (p=0.05), PCC (p=0.01) | None.
Effectiveness of speech intervention for phonological disorders: a randomized controlled trial | | | Assessment from 5/93 to 5/94 | | Male: 12 | Receptive language skills >1 SD below the mean on the Reynell Developmental Language Scales - Revised | Group 2: 4 months | | | GFTA (Goldman-Fristoe Test of Articulation) score | 8 month assessment: Group 1- higher measures for speech intelligibility (PCC, p=0.05), but no statistically significant difference on single- word phonological skills
| | | | | Female: 1 | | | | | PCC (Percentage Consonants Correct) score | Expressive language measure (MLU): no significant differences between groups at any assessment point. Group 1 had consistently higher (improved) scores than Group 2
| | | | | Group 2: mean age 41.4 months (33–55) | | | | | MLU (Mean Length of Utterance) score
| | | | | Male: 9
| | | | | Female: 4
Barratt, 1992^†^ | To compare the benefits of intensive individual speech therapy with the more traditional once weekly approach | Expressive and receptive language | Day nurseries, special play groups and nursery classes attached to schools in SW London, UK | 39 | Male: 27 | At least one SD below the mean for age on the Reynell Developmental Language Scales in comprehension, expression or both | Immediate treatment implied | Clinician administered interactive language therapy focusing on expressive and receptive skills | Provided over 6 months either weekly (40 min), or as 2 intensive therapy blocks (40 min 4 days a week for 3 weeks in each 3 month block). | Reynell Expressive and Receptive scales | Both groups showed improvement in comprehension (p=0.07 for intensive group, p=0.02 for weekly group). Both groups showed improvement in expression scores, but the intensive therapy showed significantly greater improvement (p≤ 0.01 for intensive group, p=0.18 for weekly group) | The children in the intensive therapy group built up a relationship with the clinician quicker than those in the weekly group
Trial of intensive compared with weekly speech therapy in preschool children | | | | | Female: 12 | | | 21 participants received weekly therapy and 18 received intensive
| | | | | Age range: 37–43 months
Cole, 1986^†^ | To examine effectiveness of two intervention techniques | Syntax, semantics, and pragmatics | Classrooms in the Experimental Education Unit at the University of Washington | 44 | Male: 34 | A score of 1.5 SD below the mean for age on either the Peabody Picture Vocabulary Test-Revised (PPVT-R), Form L; the Northwestern Syntax Screening Test, receptive section (NSST-R); the Preschool Language Scale (PLS), verbal ability or auditory comprehension subtests; or a Developmental Sentence Score (DSS) one full point below the 10th percentile | Immediate treatment implied | Clinician administered intervention using either a directive or an interactive approach | 600 minutes a week given for 8 months. | MLU (Mean Length of Utterance) score | There was little difference between the effectiveness of the direct-instruction program and the interactive program | None
Direct language instruction and interactive language instruction with language delayed preschool children: a comparison study | | | | | Female: 10 | | | 19 participants received directive approach, 25 participants received an interactive approach | | Preschool language scale: overall scores
| | | | | Age range: 38–69 months | | | | | Basic language concepts test
| | | | | | | | | | Peabody Picture Vocabulary Test-Revised (PPVT-R)
Courtright, 1979^†^ | To determine the effectiveness of a third-person modeling approach. | Expressive language | Children were seen in speech and language therapy clinics | 36 | Male: 24 | All subjects fell below the 10th percentile rank for age on the Developmental Sentence Score (DSS) | Immediate treatment implied | Clinician administered syntax intervention looking at effectiveness of mimicry and modeling approaches: | 5 months | Utterances correct on 20 unusual sentences | Scores improved on the Preschool Language Scale (PLS) (p<0.001) for all children | None
Imitative modeling as a language intervention strategy: The effects of two mediating variables | To determine the amount imitative modeling increases the efficacy of interventions | | | | Female: 12 | | | 12 participants in mimicry condition
| | | | | Age range: 47–83 months | | | 12 participants in modeling condition
| | | | | | | | 12 participants in 3rd person modeling condition
Evans (unpublished)^†, ‡^ | Not reported | Not reported | Not reported | 60 | Children from middle class area | At baseline children had to have Receptive Expressive Emergent Language (REEL) scores 1 SD below mean | Not reported | Parent administered general language intervention with training from clinician, WILSTAAR intervention: | Not reported | REEL Language Quotients | All children improved regardless of therapy (p<0.01). The Visualising and Verbalising technique was not a significantly better intervention than the traditional method used | None
The Kenilworth project: A randomised controlled trial of WILSTAAR | | | | | Age: 8 months | | | 24 participants assigned to WILSTAAR condition
| | | | | Gender mix not stated | | | 36 participants assigned to no treatment condition
Fey, 1993*^, †^ | To test the effectiveness of two broadly based grammar facilitation programs, one administered by a speech-language pathologist and the other by parents | Syntax and morphology | Children were recruited through advertisements and referrals from physicians and seen at a research clinic | 29 | Participants do not meet all criteria usually stipulated for specific language impairment. | Developmental Sentence Score (DSS) below the 10th percentile for the lower of chronological or mental age | Immediate (N=21) | All treatment sessions were conducted by a speech-language pathologist and included focused simulation procedures and cyclical goal-attack strategies. Each child had 4 specific treatment goals. Goals were presented in a cyclical manner, with one targeted each week. When a child began to use a target productively in the group sessions in clinician treatment or in monthly clinic sessions in parent treatment, the goal was dropped or combined with another existing related goal | 20 weeks | Primary: DSS (Developmental Sentence Score) | Clinician Group vs. Delayed-Treatment Group: The clinician group's DDS scores, Main Verb scores, and percentage of grammatically well-formed sentences were significantly higher (p=0.0005, p=0.004, and p=0.0005, respectively) than the delayed-treatment group | None
Two approaches to the facilitation of grammar in children with language impairment: An experimental evaluation | | | | | Clinician Treatment Group: mean age 54.7 months (SD 6.1) | | Delayed 4.5 months (N=8) | Clinician Treatment: 1-hour individual session and two 1-hour group sessions per week for 20 weeks. Each individual session began with a highly structured activity with imitation of the target for that week and of a language form contrastive with the target | | Mean Main Verb score per sentence | Parent Group vs. Delayed-Treatment Group: The parent group's DDS scores, Main Verb scores, and percentage of grammatically well-formed sentences were significantly higher (p=0.0001, p=0.04, and p=0.03, respectively) than the delayed-treatment group
| | | | | Male: 6 Female: 5 | | | Parent Treatment: 2-hour group session per week for parents (12 weeks) then once per month (8 weeks). 3 home visits by pathologist during first 12 weeks. 1 hour monthly clinic visit with individual sessions for parent and child (final 8 weeks) | | Mean Personal Pronoun score per sentence | Clinician Group vs. Parent Group: There were no differences between the clinician group and the parent group on DDS scores, Main Verb scores and percentage of grammatically well-formed sentences
| | | | | Parent Treatment Group: mean age 56.2 months (SD 7.2) | | | | | Percentage of sentences awarded a Sentence Point
| | | | | Male: 7 Female: 3
| | | | | Delayed Treatment Group: mean age 55.8 months (SD 6.3)
| | | | | Male: 8 Female: 1
Fey, 1994^†^ | To determine if a clinician-administered intervention produces better gains in phonology | Phonology | Children were recruited through advertisements and referrals from physicians and seen at a research clinic (from pool from Fey, 1993) | 26 | Male: 17 | Subjects from Fey, 1993 study | Immediate in Subgroup 1 and Subgroup 3 (N=21) | Parent or clinician administered expressive syntax intervention based on focused stimulation: | 10 months for Subgroups 1 and 2 | Percentage of consonants correct derived from the Assessment of Phonological Processes - Revised (AAP-R) | Both the clinician and parent groups performed better than the control group (p=0.0006) | None
Effects of grammar facilitation on the phonological performance of children with speech and language impairments | | | | | Female: 9 | Developmental Sentence Score (DSS) below the 10th percentile for the lower of chronological or mental age | Delayed 5 months in Subgroup 2 (N=9) | 10 received clinician therapy | 5 months for Subgroup 3
| | | | | Age range: 44–70 months | | | 8 received parent therapy
| | | | | | | | 8 received delayed therapy
Fey, 1997^†^ | To evaluate the effects of either 5 months of intervention or 5 months of no intervention following completion of the first 5-month phase | Phonology | Children were recruited through advertisements and referrals from physicians and seen at a research clinic (from pool from Fey, 1993) | 28 | Age range: 44–70 months | Subjects from Fey, 1993 study | Immediate treatment implied. | Parent or clinician administered expressive syntax intervention based on focused stimulation provided in addition to that which was provided in Fey 1993: | 10 months for two groups | Developmental Sentence Scores (DSS): composite, verbs, sentence points | The clinician group had higher DSSs and main verb scores at the end of Phase 2 than at the end of Phase 1 (p=0.01 and p=0.03, respectively). The parent group had higher DSSs at the end of Phase 2 than at the end of Phase 1 (p=0.04). The reduction in DSS gains for the dismissal group over Phase 2 compared to those over Phase 1 was statistically significant (p=0.02). The clinician group had a smaller improvement in well-formed sentences over Phase 2 than over Phase 1 (p=0.03) | None
Two models of grammar facilitation in children with language impairments: Phase 2 | | | | | | Developmental Sentence Score (DSS) below the 10th percentile for the lower of chronological or mental age | | 9 had further parent treatment as Fey 1993 | 5 months for one dismissal group
| | | | | | | | 9 had further clinician treatment as Fey 1993
| | | | | | | | 10 had no more treatment except the 4.5 month treatment received in Fey 1993
Gibbard, 1994*^, †^ | To examine the effectiveness of a parent trained intervention versus no intervention | Expressive language | Local health center where children were referred for speech and language therapy | 36 | Male: 25 | Vocabulary of <30 single words | Immediate | Parental administered expressive syntax intervention emphasizing how to maximize language use in everyday environment: | An average of 40 minutes per week over 6 months | Reynell Expressive measure | The mean scores improved for both the experimental and the no-intervention control groups, but the experimental group had larger gains on all measures (p=0.008 for language sample one word scores and p=0.000 for all other measures) | None
Study 1 | | | | | Female: 11 | | | 18 received parental intervention | | Language sample one word scores and total scores
Parental-based intervention with pre-school language-delayed children | | | | | Age range: 27–39 months | | | 18 received delayed intervention | | Renfrew Action Picture Test information
| | | | | Majority of participants in social classes I, II, or IIIM | | | | | Mother's description of vocabulary and phrase complexity
| | | | | Mean mother age: 30 | | | | | MLU (mean length of utterances) from language sample
| | | | | Mean father age: 33
Gibbard, 1994^†^ | To examine the effectiveness of a parent trained intervention versus a direct intervention | Expressive language | Local health center where children were referred for speech and language therapy | 25 | Male: 19 | Vocabulary of ≤30 single words | Immediate | Clinician or parent administered expressive syntax intervention | Clinician therapy 30 minutes per week for 6 months | Reynell expressive measure | The parental involved approach made more gains than the direct approach on all measures, but only the mean length of utterances was statistically significant (p=0.008). The gains made by the parent involved group was statistically significant compared to the control group on all the measures (Reynell, p=0.018; Derbyshire one word scores, p=0.004, Derbyshire total scores, p=0.000; Renfrew, p=0.005; and mean length of utterances, p=0.000). The gains made by the direct approach group were statistically significant compared to the control group on two measures (Derbyshire total scores, p=0.007 and mean length of utterances, p=0.000) | None
Study 2 | | | | | Female: 6 | | | Controls received a cognitive parent therapy based on Portage: | Parent therapy an average of 40 minutes per week for 6 months | Language sample one word scores and total scores and MLU (mean length of utterances)
Parental-based intervention with pre-school language-delayed children | | | | | Age range: 27–39 months | | | 8 received clinician therapy | | Parent report of vocabulary and phrase complexity
| | | | | Majority of participants in social classes II, IIIM, and IIIN | | | 9 received parent therapy | | Renfrew Action Picture Test information
| | | | | Average mother age: 28 and 29 | | | 8 received control therapy
| | | | | Average father age: 29 and 33.5
Girolametto, 1996*^, †^ b | To examine the effects of a focused stimulation language intervention on children's' vocabulary and language development | Expressive vocabulary | Children were recruited from waiting lists for parent programs offered at two agencies in metropolitan Toronto, Canada | 25 | Age range: 23–35 months | Vocabulary size in the lower 5th percentile for age measured by McArthur Communicative Development Inventories (CDI) | Immediate | Parental administered expressive vocabulary intervention based on HANEN principles and adapted for focused stimulation: | 150 minutes per week for 11 weeks | Vocabulary and phrase complexity as determined by the McArthur Communicative Development Inventories (CDI) | Children who received treatment had larger vocabularies (p<0.02) and used a greater number of different words (p<0.01) compared to the control group. Those who received treatment used more structurally complete utterances and more multiword utterances than those in the control group (p<0.04 and p<0.01, respectively) | Mother's language interactions with child changed (language input slower, less complex, and more focused after treatment)
Interactive focused stimulation for toddlers with expressive vocabulary delays | | | | | No gender details given | | | 12 received parent intervention | | Number of different words and utterances from a language sample | | Few words/minute p≤0.01
| | | | | | | | 13 received delayed intervention | | Post test probes for target words | | Shorter utterances p<0.01
| | | | | | | | | | Control word measures, target words in interaction, multi-word utterances | | Used more target words and focused stimulation of target words p<0.01
Girolametto, 1996*a | To examine whether children in an experimental group would learn more words than children on a waiting list (control group) | Expressive and receptive vocabulary | Children were recruited from waiting lists for parent programs offered at two agencies in metropolitan Toronto, Canada | 16 | Male: 11 | Delayed in the acquisition of vocabulary as measured by the Communicative Development Inventory (CDI) | Immediate | Parental administered expressive vocabulary intervention based on HANEN principles and adapted for focused stimulation: | 150 minutes per week for 10 weeks | Parent report of vocabulary size | Those in the experimental group produced significantly more target words at post-test than the control group (p<0.02). Those in the experimental group used an average of twice as many target words as those in the control group at post-test | Treatment group: use of symbolic play gestures increased p<0.03.
The effects of focused stimulation for promoting vocabulary in young children with delays: a pilot study | | | | | Female: 5 | | | 8 received parent therapy | | Number of target words in probe exercise | | Externalizing aggressive/destructive behavior decreased p<0.02.
| | | | | Age range: 22–38 months | | | 8 received delayed therapy | | | | Internalizing aggressive/destructive behavior no effect
Girolametto, 1997^†^ | To examine the impact of a focused stimulation intervention on the vocabulary, language, and emerging phonological skills of late talkers | Phonology | Children were recruited from waiting lists for parent programs offered at two agencies in metropolitan Toronto, Canada. | 25 | Male: 22 | Vocabulary size in the lower 5th percentile for age measured by McArthur Communicative Development Inventories (CDI) | Immediate | Parental administered expressive vocabulary intervention based on HANEN principles and adapted for focused stimulation: | 11 weeks | Different vocalization | There was no difference between groups on the number of vocalizations made. Children who received treatment used Level 3 vocalizations more than the controls (p<0.01). Those that received treatment also used a greater inventory of consonants in all three classes | None
Effects of lexical intervention on the phonology of late talkers | | | | | Female: 3 | | | 12 received parent intervention | 8 2.5 hour evening sessions | Syllable structure at level 1, 2, 3
| | | | | Age range: 23–35 months | | | 13 received delayed intervention | 3 home sessions | Consonants inventory: early, middle, late
| | | | | | | | | | Consonant position: initial and final
| | | | | | | | | | Proportion of consonants correct
Glogowska, 2000^†^ | To compare routine speech and language therapy against 12 months of “watchful waiting” | Expressive and receptive language and phonology | 16 community clinics in Bristol. Children were enrolled between December 1995 and March 1998 | 159 | Male: 120 | Standardized score <1.2 SD below the mean on the auditory comprehension part of the Preschool Language Scale (PLS). Standardized score >1.2 SD below the mean on auditory comprehension, but <1.2 SD below the mean on the expressive language part of the PLS. Auditory and expressive language scores >1.2 SD below the mean but with an error rate of at least 40% in production of fricative consonants and /or velar consonants and/or sounds occurring after a vowel among the 22 words included in the phonological analysis | Immediate treatment implied | Clinician administered intervention focusing on a variety of language areas. | Therapy continued for an average of 10 minutes per week for 8.4 months | Preschool Language Scale (PLS): auditory comprehension and expressive language | Although all outcome measures were in favor of the therapy group only one measure reached the significant level (auditory comprehension, p=0.025) | No significant difference for play level or attention level
Randomised controlled trial of community based speech and language therapy in preschool children | | | | | Female: 39 | | | 71 received clinician intervention | | Phonological errors
| | | | | Age range: 18–42 months | | | 88 received delayed intervention
| | | | | Just over half of the children were receiving child care.
| | | | | Most mothers had completed “O” level education.
| | | | | A minority either had no qualifications or had “A” levels.
Glogowska, 2002 | To examine the effectiveness and acceptability of community speech and language therapy provision | Expressive and receptive language and phonology | Children were referred to their local speech and language therapist and seen at these clinics | 159 | Age range: 42 months or younger | All subjects had slow speech/language development and were referred by their local speech and language therapy clinic. No measures were specified | Immediate | Clinician administered intervention focusing on a variety of language areas. | 12 months | Not reported | Only one of the five outcomes showed significantly more improvement in the therapy group versus the control group (receptive language, p=0.025) | The treatment group showed improvement in family's response to child (p=0.14). The therapist made parent feel better (p=0.045) in the treatment group
A multimethod approach to the evaluation of community preschool speech and language therapy provision | | | | | | | | Children received either clinician intervention or delayed intervention, N not specified for each group.
Lancaster, 1991*^, †, ‡^ | To examine the effectiveness of a parent administered intervention | Phonology | Children were referred to a speech and language clinic and subjects were selected from them | 15 | Males: 12 | Children needed to have a standard score of below 80 on the Edinburgh Articulation Test (EAT) | Immediate treatment implied | Clinician administered phonology intervention | Average of 17 minutes of therapy per week for 6 months | Composite Deviancy Score | Those in the treatment group made significantly more gains than those in the control (p<0.05). There was no difference between the direct therapy or the parent administered therapy | None
The effectiveness of parent administered input training for children with phonological disorders | | | | | Females: 3 | | | Clinician provided an eclectic approach, parent therapy was based on auditory bombardment therapy | Parents were trained an average of 9 minutes per week for 6 months
| | | | | Age range: 40–53 months | | | 5 received clinician therapy
| | | | | Majority had family history of speech difficulties | | | 5 received parent therapy
| | | | | | | | 5 received delayed therapy
Law, 1999^†, ‡^ | To compare two intervention: a clinician lead and a parent lead approach | Expressive and receptive language | Not reported | 38 | Males: 24 | Children were below 1.5 SD on comprehension measures | Not reported | Clinician or parent administered expressive and receptive language intervention | Clinician therapy: 450 minutes per week for 6 weeks | Preschool Language Scale (PLS): expressive and receptive | There were no differences between groups on speech and language measures | Parent's rating of child's behavior and positivity towards their child went up as well as child's rating of their sense of self-esteem (p=0.03, p=0.04, p=0.05; respectively)
A comparison of two methods for providing intervention to three year old children with expressive/receptive language impairment | | | | | Females: 14 | | | Clinician therapy focused on auditory processing and word mapping | Parent therapy: 150 minutes per week for 10 weeks | Parent report: vocabulary, phrase complexity, language sample: total communication acts, MLU (mean length of utterances)
| | | | | Age range: 33–39 months | | | Parent therapy used HANEN principles
| | | | | Majority were of lower SES and ethnic minorities | | | 17 received clinician therapy
| | | | | | | | 11 received parent therapy
| | | | | | | | 10 received delayed therapy
Mulac, 1977^†^ | To determine the extent to which clinically acquired syntax skills generalize to extraclinic stimulus settings | Syntax | Children were seen in speech and language therapy clinics and parents completed some activities at home | 9 | Males: 6 | Failure to pass the “is interrogative” item on the Programmed Conditioning Language Test (PCLT) | Immediate treatment implied | Clinician administered Monterey operant language program with additional outdoor and home activities for the children in the program and additional lessons condition | Average of 67 minutes per week for 4 weeks | Extra clinic measures of “is” interrogative | Only the group that received the language program plus extended transfer made a significant improvement (p<0.01) | None
Generalization of an operant remediation program for syntax with language delayed children | | | | | Females: 3 | | | 3 received articulation therapy
| | | | | Age range: 52- 75 months | | | 3 received Monterey language program
| | | | | | | | 3 received Monterey language program and additional exercises to facilitate generalization
Munro, 1998^†^ | To assess the efficacy of therapy for children have articulation deficits (word-initial velar plosives) | Articulation | Children were seen in general pediatric services | 13 | Male: 6 | Over 1.5 SD below the mean for age on the Renfrew Action Picture Test | Immediate for treatment group Delayed group received treatment later, but not reported in this study | Clinician administered intervention for phonology /k/ and /g/ | 60 minutes per week for 6 weeks | Edinburgh Articulation Test (EAT) | Preliminary data, no results were presented | Not reported
Efficacy of speech and language therapy for particular speech sounds in children | | | | | Female: 5 | | | 7 received immediate therapy | | Target sounds in initial position
| | | | | Age range: 47–65 months | | | 4 received delayed therapy | | Re-telling a story with target sounds
| | | | | | | | | | Repetition of five lexical items four times each
Reid, 1996*^, †, ‡^ | To assess the efficacy of the Metaphon approach | Phonology and receptive vocabulary | Not reported | 30 | Age range: 42–66 months | Children had to get less than 85SS on the Edinburgh Articulation Test (EAT) | Immediate treatment is implied | Clinician administered phonology intervention using Metaphon | 30 minutes per week for 10 weeks | EAT Occurrence of phonological process: subtest from Metaphon resources | There was a significant improvement in gains on the EAT for the Phase 1 plus Phase 2 group (p<0.02). The 10-week intervention group made significant gains on test of phoneme awareness (p<0.03) only | None
The effectiveness of therapy for child phonological disorders: the Metaphon approach | | | | | No information on gender | This is a sub-group analysis of an on-going trial; groups acknowledged to be unequal and median figures reported | | 8 received metaphon stage 1 only
| | | | | | | | 7 received metaphon stages 1 and 2
| | | | | | | | 15 received delayed therapy
Robertson, 1997 | To examine the effects of peer modeling using the same peer throughout the intervention on children with speech and language impairments | Expressive and receptive language | Children were enrolled in a language-based early childhood classroom | 6 | Male: 4 | Performance at or near 2 SD below the mean on standardized measures of receptive and expressive language; measures not reported | Immediate | Play intervention for expressive narrative language: | 15 minutes per week for 3 weeks | Language sample: number of words in script, number of different words, number of play related themes | Both children in the experimental group showed significant gains in number of words used, number of different words used, and number of linguistic markers used | Both children in the experimental group showed significant increases in the number of play-theme-related acts
Study 2 | | | | | Female: 2 | | | 4 participants played with each other in pairs
The influence of peer models on the play scripts of children with specific language impairment | | | | | Mean age: 54 months (range 48–57 months) | | | 2 participants were paired with a normal peer
Robertson, 1997^†^ | To examine the effects of peer modeling on children with speech and language impairments | Expressive and receptive language | Children were enrolled in a language-based early childhood classroom | 20 | Male: 13 | Performance at or near 2 SD below the mean on standardized measures of receptive and expressive language; measures not reported | Immediate | Play intervention for expressive narrative language: | 20 minutes per week for 3 weeks | Language sample: number of words in script, number of different words, number of play related themes | Those in the experimental group produced significantly more words than those in the control group immediately after treatment and at follow-up (p<0.0001). The experimental group demonstrated greater verbal productivity and employed more lexical diversity than the control group. Also, the experimental group made significantly more gains in the use of linguistic markers than the control group (p<0.0001) | Play-theme-related acts increased (p<0.0001) for the treatment group
Study 1 | | | | | Female: 7 | | | 10 participants played with each other in pairs
The influence of peer models on the play scripts of children with specific language impairment | | | | | Mean age: 50 months (range 36–60 months) | | | 10 participants were paired with a normal peer
| | | | | Mean maternal education: 14 years
Robertson, 1999^†^ | To examine the effects of early language intervention on the development of late-talking toddlers | Expressive and receptive language and phonology | Children were recruited from the community and seen at a research clinic | 21 | Male: 12 | Demonstrated significant delays in the acquisition of language measured by the Preschool Language Scale - 3 and the Bayley Scales of Infant Development (BSID-II) | ≤1 week | Clinician administered intervention for expressive vocabulary and syntax | 150 minutes per week for 12 weeks | Language sample: MLU (mean length of utterances), total number of words | Compared to children in the control group children in the treatment group demonstrated significantly greater increases in mean length of utterances (p=0.003), the total number of words used (p=0.000), lexical diversity (p=0.000), in their reported vocabulary size (p=0.000) and percentage of intelligible utterances (p=0.000) | Treatment group had an increase in socialization skills (p=0.003) not merely reflective of the language increases; parental stress decreased (p=0.000) for the treatment group
Effects of treatment on linguistic and social skills in toddlers with delayed language development | | | | | Female: 9 | | | Child-centered approach to provide general stimulation | | Parent report of vocabulary (MacArthur Communicative Developmental Invetory-Words and Sentences (CDI))
| | | | | Age range: 21–30 months | | | 11 received clinician intervention
| | | | | All participants from middle class households | | | 10 received delayed intervention
Ruscello, 1993^†^ | To develop and implement a service delivery model which incorporates parental involvement and computer-based instruction | Phonology | Children were seen at the Allen Hall Speech and Hearing Center | 12 | Male: 8 | A composite score at the 15th percentile or lower for age on the Khan-Lewis Phonological Analysis | Immediate treatment implied | Clinician administered phonology intervention with additional intervention from parents using Speech Viewer software | 120 minutes per week for 8 weeks | 30-item naming sample including words, phrases, and sentences | Both groups showed significant improvement between baseline and follow-up (p≤0.001 for both Group 1 and Group 2) | Parents indicated that their children enjoyed using the computer-based program
The use of different service delivery models for children with phonological disorders | | | | | Female: 4 | | | Group 1 received clinician intervention | | Khan Lewis Phonological Assessment
| | | | | Age range: 49–68 months | | | Group 2 received half of treatment from parent and half from clinician
Rvachew, 1994^†^ | To demonstrate that speech perception training can facilitate sound production learning | Phonology | Children were referred by a speech and language pathologist who diagnosed them | 27 | Males: 21 | Children were referred by a speech and language pathologist who had assessed the child and diagnosed a significant phonological delay | ≤1 week | Clinician administered phonological therapy with additional auditory discrimination task | 45 minutes per week for 6 weeks | Auditory word discrimination test | Both Groups 1 and 2 performed significantly better at post-test than Group 3 (p=0.03 and p=0.01, respectively). Group 1 and Group 2 were not significantly different at post-test (p=0.52). Children in Groups 1 and 2 progressed further during production training than children in Group 3 | None.
Speech perception training can facilitate sound production learning | | | | | Females: 6 | | | Group 1: 10 received experimental auditory discrimination task | | Object naming speech sample
| | | | | Age range: 42–66 months | | | Group 2: 9 received a tradition auditory discrimination task
| | | | | | | | Group 3: 8 received a discrimination game not based on minimal pairs
Rvachew, 2001^†^ | To investigate the effectiveness of two different sets of target-selection criteria | Phonology | Children were referred to a research clinic by clinician | 48 | Mean age: 50 months | Moderate to severe phonologic delays, 39 fell below the 1st percentile whereas all fell below the 9th percentile | ≤1 week | Clinician administered phonological intervention with traditional therapy targeting the early developing sounds was compared to intervention that targeted later developing sounds: | 30 minutes per week for 12 weeks | Probes for each target sound | Children in the ME group improved more at final assessment than those in the LL group (p=0.004). Generalization of learning for treated phonemes from the first assessment to the final assessment was significantly greater for the ME group than the LL group (p=0.001). Both the ME and the LL groups performed better than a control group of children who didn't receive any treatment (p=0.009) | Parents were more satisfied with treatment progress in the ME group (p=0.035)
The effect of target-selection strategy on phonological learning | | | | | | | | 24 received treatment for early developing sounds (ME group) | | Productive phonological knowledge profile
| | | | | | | | 24 received treatment for late developing sounds (LL group) | | Percentage of consonants correct in conversation
Schwartz, 1985*^, †^ | To examine the effects of intensively engaging language-impaired children at the one-word utterance level in vertical structures | Lexical acquisition | Pre-testing was conducted in the home and treatment administered in clinic | 10 | All male | Expressive vocabularies ranged from 25–60 words and all children exhibited specific language impairments. Comprehension was 6–9 months below mental age measured by the Test for Auditory Comprehension of Language or the Auditory Comprehension subtest of the Preschool Language Scale | Immediate treatment implied | Clinician administered syntax intervention: | Therapy administered over 3 weeks | Multiword utterances used with the target stimuli | Children in the experimental group improved significantly from pre-test to post-test (p<0.05) | None.
Facilitating word combination in language-impaired children through disclosure structure | | | | | Age range: 32–40 months | | | 8 received experimental intervention
| | | | | | | | 2 served as control group receiving intervention without target utterances
Shelton, 1978*^, †^ | To compare two parent-administered listening treatments and a control group | Articulation/Phonology | Children were from nursery schools or pediatric offices; they were seen either at their school or in their home | 60 | Age range: 36–54 months | Below the cutoff score for age on the Templin-Darley Articulation Screening Test | Immediate treatment implied | Parent administered speech programs | 57 days (listening for 5 minutes per day, and reading and talking for 15 minutes per day) | Auditory association subtest of the Illinois Test of Psycholinguistic Abilities | Only the noise subtest of the Test of Auditory Discrimination showed a significant improvement for the listening and control groups compared to the reading-talking group (p=0.03). There were no other significant differences between groups | None.
Study 1 | | | | | Bilingual children were included with 2 in each condition | | | Listening therapy based on auditory discrimination compared to more traditional reading and talking therapy and delayed treatment | | McDonald Screening Articulation test
Assessment of parent-administered listening training for preschool children with articulation deficits | | | | | | | | 20 received experimental listening therapy
| | | | | | | | 20 received a reading and talking therapy
| | | | | | | | 20 received delayed treatment
Sutton, 1999^†, ‡^ | Not reported | Not reported | Not reported | 22 | Age: 7 months | Children had to fail WILSTAAR screen and have a standard score of below 85 on Receptive Expressive Emergent Language (REEL) | Not reported | WILSTAAR: Parent administered general language intervention designed to facilitate language development in the first year of life | Experimental group received 5 home visits | Receptive Expressive Emergent Language (REEL) language quotients | Not reported | Not reported
Investigating WILSTAAR | | | | | | | | 13 received WILSTAAR intervention | Control group received 2 visits over four months
| | | | | | | | 9 were assigned to no treatment control
Wilcox, 1991^†^ | To examine the effectiveness of classroom versus individual interventions | Lexical acquisition | Children were recruited from a speech and hearing clinic and community early intervention program | 20 | Age range: 20–47 months | Children had to score 1.5 SD below mean on both expressive and receptive scales of the sequenced inventory of communication development (SICD) | Immediate treatment implied | Clinician administered expressive vocabulary intervention: | 90 minutes per week for 3 months individually and 360 minutes per week for 3 months in groups | Overall use of target words in clinic sessions | Children in the classroom treatment group used more words in the home setting (M=5.00) than those in the individual treatment group (M=2.80), and used more at home than in the treatment setting (M=3.00) | None.
Early language intervention: A comparison of classroom and individual treatment | | | | | | | | 10 received individual intervention
| | | | | | | | 10 received classroom based group intervention