# Appendix 8. Quality Ratings of Screening Instrument Studies

Author, Year | Groups Similar at Baseline | Eligibility Criteria Specified | Adequate Sample Size (>50) | Adequate Attrition (≤10%) | Credible Reference Standard Used | Screening Test Adequately Described | Reference Standard Interpreted Independently | Quality Rating
Alberts, 1995 | Yes | Yes | Yes (59) | N/A | Yes (McCarthy-Verbal) | Yes | Yes | Good
Allen, 1987* | NR | No | Yes (182) | N/A | Yes (SICD) | Yes | Yes | Fair
Black, 1988* | Yes | No | No (48) | N/A | Yes (REEL and Bayley) | Yes | Yes | Poor
Blaxley, 1983* | NR | Yes | Yes (90) | N/A | No (DSS) | Yes | Yes | Fair
Bliss, 1984* | Yes | No | Yes (602) | N/A | Yes (SICD) | Yes | No | Fair
Borowitz, 1986* | NR | Unclear | Yes (71) | N/A | Yes (PLS) | Yes | Yes | Fair
Burden, 1996 | Yes | Yes | Yes (425) | N/A | Yes (Clinical Judgment) | Yes | Yes | Good
Chaffee, 1990* | N/A | Yes | Yes (152) | N/A | Yes (Reynell) | Yes | Yes | Good
Clark, 1995* | NR | Unclear | Yes (99) | N/A | Yes (SICD) | Yes | Yes | Fair
Conti-Ramsden, 2003 | Yes | Yes | Yes (64) | N/A | Yes (Clinical Judgment) | Yes | No | Fair
Coplan, 1982* | NR | Yes | Yes (191) | N/A | Yes (Formal language and psychometric testing) | Yes | No | Fair
Dixon, 1988* | NR | No | No (40) | N/A | Yes (SLP Judgment) | Yes | Yes | Poor
Dodge, 1980* | NR | No | Yes (486) | N/A | Yes (Formal language assessment) | Yes | No | Fair-poor
Drumwright, 1973 | Yes | Yes | Yes (1455) | N/A | Yes (TNDAST) | Yes | No | Fair
Feeney, 1996* | Yes | No | Yes (199) | N/A | Yes (SLP Judgment) | No | No | Fair
German, 1982* | N/A | Yes | Yes (84) | N/A | Yes (SICD and Bayley or McCarthy) | Yes | Yes | Good-fair
Glascoe, 1991* | Yes | Yes | Yes (157) | N/A | Yes (SLP Assessment) | Yes | Yes | Good
Glascoe, 1993* | N/A | Yes | Yes (89) | N/A | Yes (Criterion battery^†^) | Yes | Yes | Fair
Gray, 2003 | Yes | Yes | No (44) | N/A | Yes (SPELT-II) | Yes | Yes | Poor
Klee, 1998* | Unclear | Yes | Yes (64) | N/A | Yes (Infant MSEL) | Yes | Yes | Good-fair
Klee, 2000 | Unclear | Yes | Yes (64) | N/A | Yes (MSEL) | Yes | Yes | Fair
Laing, 2002 | NR | Yes | Yes (458) | N/A | Yes (RDLS) | Unclear; parent based and judgment used | Yes | Fair
Law, 1994* | NR | Yes | Yes (217) | N/A | Yes (RDLS) | Yes | Yes | Good-fair
Leppert, 1998 | NR | Yes | Yes (70) | N/A | Yes (BSID II) | Yes | Yes | Fair
Levett, 1983* | Yes | Yes | Yes (140) | N/A | Yes (RDLS, G-F, LARSP) | Yes | Yes | Fair
Macias, 1998 | Yes | Yes | Yes (78) | N/A | Yes (BSID II) | Yes | Yes | Fair
McGinty, 2000* | Yes | Yes | Yes (200) | N/A | Yes (RDLS) | Yes | Yes | Poor
Merrell, 1997 | Yes | Yes | No (40) | N/A | Yes (K-ABC and SPELT-II) | Yes | Yes | Poor
Oakenfull, 2001 | NR | NR | Yes (177) | N/A | Yes (REEL) | No | No | Poor
Plante, 1995 | Yes | Yes | No (40) | N/A | Yes (K-ABC and SPELT-II) | Yes | Yes | Poor
Rescorla, 1989* | Yes | Unclear | Yes (81) | N/A | Yes (Bayley and Reynell) | Yes | Yes | Fair
Rescorla, 1993* | NR | Unclear | Yes (108) | N/A | Yes (Bayley and Stanford-Binet) | Yes | No | Fair
Rescorla, 2001 | Yes | No | Yes (422) | N/A | Yes (Bayley and Stanford-Binet) | Yes | No | Fair
Rescorla, 2002 | Yes | No | Yes (278) | N/A | Yes (CBCL) | Yes | No | Fair
Scherer, 1995* | Yes | Yes | Yes (60) | N/A | Yes (SLP assessment) | Yes | No | Fair
Sherman, 1996 | Yes | Yes | Yes (173) | N/A | Yes (EMLS) | Yes | No | Fair
Stokes, 1997* | NR | Yes | Yes (398) | N/A | Yes (SLP assessment) | Yes | No | Fair
Stott, 2002 | Yes | Yes | Yes (254) | No (15%) | Yes (EAT, RDLS, BPVS) | Yes | Yes | Good-fair
Sturner, 1993* Study 1 | NR | No | Yes (279) | N/A | Yes (AAPS-R) | Yes | Yes | Fair
Sturner, 1993* Study 2 | NR | No | Yes (421) | N/A | Yes (TACL-R, Templin-Darley) | Yes | Yes | Fair
Sturner, 1996* | N/A | No | Yes (76) | N/A | Yes (SLSQ) | Yes | Yes | Fair
Walker, 1989* | NR | No | Yes (77) | N/A | Yes (SICD) | Yes | No | Poor
Ward, 1984 | N/A | No | Yes (1070) | N/A | Yes (REEL) | Yes | No | Fair
Wilcox, 1998 | Yes | Yes | No (26) | N/A | Yes (Clinical Judgment) | Yes | No | Poor