# Appendix 7. Descriptions of Instruments Used in Studies

Instrument | Abbreviation | Components | Reference
Author created | | Focuses on abnormal auditory behaviors: | Ward, 1984
| | 1) Inconsistency of response to sound; 2) Failure to separate background/foreground audition; 3) Ignoring sound to abnormal degree; 4) Diminishing responses to environmental sound; 5) Inability to respond to auditory stimuli when more than minimally occupied with visual or tactile stimulation; 6) Delayed responses; 7) Habituation; 8) Localization problems; 9) Failure to repond to voice
Bankson Language Screening Test | BLST | 17 nine-item subtests designed to test expressive language organized into five categories: | Blaxley, 1983
| | 1) Semantic knowledge; 2) Morphological rules; 3) Syntactic rules; 4) Visual perception; 5) Auditory perception
*Battelle Developmental Inventory Screening Test | BDIST | Seven subsets: | Glascoe, 1993
| | 1) Personal/social; 2) Adaptive; 3) Fine motor; 4) Gross motor; 5) Expressive language; 6) Receptive language; 7) Cognitive skills
*Bayley Infant Neurodevelopmental Screener | BINS | Assesses four areas: | Macias, 1998
| | 1) Neurological functions/intactness; 2) Receptive functions; 3) Expressive functions; 4) Cognitive processes
Children's Test of Nonword Repetition | CNRep | Repeating nonwords from two different lists and repeating numbers in series. | Gray, 2003; Conti-Ramsden, 2003
Clinical Adaptive Test/Clinical Linguistic Auditory Milestone Scale | CAT/CLAMS | Includes psychometrics and speech and language milestones. | Macias, 1998; Clark, 1995; Leppert, 1998;
| | CAT
| | 19 age sets with 12 instruments and 57 items for visual motor skills.
| | CLAMS
| | 19 age sets with 3 instruments up to 24 months and 4 instruments after 24 months, includes 43 items for language skills.
Davis Observation Checklist for Texas | DOCT | Observational teacher checklist on six areas of communication: | Alberts, 1995
| | 1) Speaking (expressive language); 2) Understanding (receptive language); 3) Speech; 4) Fluency; 5) Voice; 6) Hearing
Denver Articulation Screening Exam | DASE | 34 sound elements that children are asked to produce | Drumwright, 1973
*Denver Developmental Screening Test | DDST | Four sectors: | Dodge, 1980
| | 1) Personal-social; 2) Fine motor/adaptive; 3) Gross motor; 4) Language
*Denver Developmental Screening Test - II | DDST II | Domains include: | Glascoe, 1993
| | 1) Language; 2) Fine motor-adaptive; 3) Personal-social; 4) Gross motor
*Denver Developmental Screening Test - Revised | R-DDST | Five categories: | German, 1982; Feeney, 1996
| | 1) Gross motor; 2) Language; 3) Fine motor; 4) Adaptive/personal development; 5) Social development
*Developmental Nurse Screen | | 12-item checklist for gross and fine motor skills, language development, hearing, vision, social development, and self-help skills | Stokes, 1996
*Developmental Profile-II | DP-II | Five subsets: | Glascoe, 1993; German, 1982
| | 1) Physical; 2) Self-help; 3) Social; 4) Academic; 5) Communication
Early Language Milestone Scale | | 41 items covering four areas: | Coplan, 1982; Black, 1988; Walker, 1989 Sherman, 1986
| | 1) Auditory expressive; 2) Auditory receptive; 3) Visual expressive; 4) Visual receptive
Fluharty Preschool Speech and Language Screening Test | | 35 items separated into 3 sections (A, B, C) including identification of 15 common objects (phoneme), nonverbal responses to 10 sentences (syntax), and imitation of 10 one-sentence picture descriptions. Assess identification, articulation, comprehension, and repetition | Blaxley, 1983; Sturner, 1993; Allen, 1987
General Language Screen | GLS | 11 questions about receptive and expressive language skills and one question about whether the child has any hearing difficulties | Stott, 2002
Hackney Early Language Screening Test | | 20-item test in seven sections: | Dixon, 1988; Law, 1994
| | 1) Comprehension - following instructions to manipulate toys (e.g., “Make teddy drink”); 2) Expression - tester manipulates toys and asks child questions about this; 3) Comprehension - following instructions for placing toys (e.g., “Put the spoon in the box”); 4) Comprehension - child chooses picture from three options; 5) Expression - child answers question about pictures; 6) Expression - child names objects; 7) Comprehension - child chooses picture from four options (testing comprehension of function)
Language Development Survey | LDS | 310 words arranged in 14 semantic categories. Parents indicate which words their child has spoken and describe word combinations of two or more words that their child has used | Rescorla, 1989; Rescorla, 1993; Rescorla, 2002; Klee, 1998; Klee, 2000; Rescorla, 2001
Levett-Muir Language Screening Test | | Test is divided into six sections: | Levett, 1983
| | 1) Comprehension - child is asked to pick toys from group; 2) Vocabulary - child's ability to name the toys; 3) Comprehension - using pictures child is required to respond to questions; 4) Vocabulary - child's ability to name what's in the pictures; 5) Comprehension & representation - child's ability to answer “what” and “who” questions; 6) Overall - child is asked to explain the detailed composite picture
MacArthur Communicative Development Inventory: Toddler | CDI: Toddler | Expressive language is divided into two sections: | Scherer, 1995
| | 1) Vocabulary list of 680 word options; parent is asked to check the ones their child uses; 2) Morphology and word combinations
Mayo Early Language Screening Test | MELST | General checklist with specific age-related sections including questions to parents, observation of the child, and direct testing | McGinty, 2000
*Minnesota Child Development Inventory | MCDI | 320 items for parents include five areas of their child's development: | Chaffee, 1990
| | 1) Cognitive; 2) Language; 3) Motor; 4) Social; 5) Adaptive skills
Northwestern Syntax Screening Test | NSST | 20 receptive and 20 expressive items of grammatical forms that vary in level of complexity | Allen, 1987
Parent Evaluation of Developmental Status | PEDS | Two questions for parents to elicit concerns in general and in specific areas. Other items determine reasons for parents' concerns | Glascoe, 1991
*Parent Language Checklist | PLC | Twelve questions for parents about their child's receptive and expressive language with one question assessing hearing problems | Burden, 1996
Pediatric Language Acquisition Screening Tool for Early Referral | PLASTER | Communication development milestones by age with seven individual areas. Each area contains 10 questions (five relate to receptive language and five relate to expressive langauge) | Sherman, 1996
Screening Kit of Language Development | SKOLD | Vocabulary comprehension, story completion, sentence completion, paired sentence repetition with pictures, individual sentence repetition with pictures, individual sentence repetition without pictures, auditory comprehension of commands | Bliss, 1984
Sentence Repetition Screening Test | SRST | 15 sentences repeated one at a time by the child after demostration by the tester | Sturner, 1996
Structured Photographic Expressive Language Test - Preschool | SPELT-P | 25-items Child is presented with a picture and prompted to produce a sentence about it | Plante, 1995
Structured Screening Test | | 20 questions covering both expressive and receptive language skills | Laing, 2002
Test for Examining Expressive Morphology | TEEM | 54-items targeting a variety of morphosyntactic structures using a sentence completion task | Merrell, 1997
Wilcox African-American English Screening Test of Articulation | WAAESTA | Includes 50 words targeting African-American Vernacular English | Wilcox, 1998
*WILSTAAR Screen | | Description not available | Oakenfull, 2001

* Speech and language are part of a broader screening instrument.