# Appendix 6. Evidence Table: Studies of Risk Factors

Author, Year | N | Study Design | Type of Disorder | Setting | Inclusion/Exclusion Criteria | Age (Months) | Assessment Method | Population | Risk Factors Studied | Results
Brookhouser, 1979 | 24 | Cross sectional | Language delay - moderate to severe levels | Sample from Boys Town Institute was taken from a larger population referred for evaluation | [underlined: Inclusion:] | 28 – 62 (mean 44) | Multi-disciplinary intake (history, otolaryngologist evaluation, audiological, speech and language standardized tests) | One or more risk factors were present in all study children, 87.5% had two or more. Otitis media as a sole factor accounted for 12 (50%) of children | HEARINGS RISK: H=history of family communication disorder; E=ear nose and throat deformities; A=anoxia at birth or low APGAR score; R=prescription for ototoxic or teratogenic drugs during pregnancy; I=maternal illness during pregnancy including infections of preeclampsia; N=neonatal intensive care or prolonged hospital stay for infant; G=growth retardation; S=stress factors in delivery; R=recurrent otitis media beginning before 2 years of age with surgical intervention and/or hearing loss; I=serious childhood illness with a fever of 104°F for a period greater than 24 hours; S=seizures diminished sucking reflex, or other signs of CNS dysfunction; K=knocked out; head trauma with loss of consciousness or bloody otorrhea; S=subjectively difficult to test audiologically | One factor (serious childhood infections) was significantly related to severity of receptive language delay (t=3.160)
| | | | | 1 Native English speakers in U.S. with English speaking parents; 2 No significant retardation; 3 Eight months or more delay below chronologic age in one of two language categories
Campbell, 2003 | 639 | Case control | Speech delay (transcriber can gloss ≤75% of words or speech sample contains errors not expected of a 3 year old.) | Pittsburgh, PA (2 urban, 2 suburban, and 2 small town or rural practices) | [underlined: Exclusion:] | 36 | Family questionnaire on enrollment; pneumatic otoscopic evaluations; individual testing session with examiners blinded to child's family history of communication disorders, maternal education level, otitis media experience and health insurance status; included standardized and nonstandardized measures; hearing test of trial patients; transcription of consecutive utterances in 15 minute speech sample by assistants blinded to all participant information | Cases=398 (90 days of continuous bilateral otitis media or 135 days of continual unilateral otitis media) | 1 Male sex; 2 FH of developmental communication disorder; 3 Low maternal education; 4 Low socioeconomic level; 5 African-American Race; 6 Prolonged otitis media | 1 Male sex, OR=2.19 (95% CI = 1.38–3.47);; 2 Positive family history, OR=1.67 (1.06–2.62);; 3 Low maternal education, OR=2.58 (1.49–4.48);; 4 Medicaid, OR=1.59 (1.02–2.49); but no longer significant when controlling for other factors;; 5 Race not significant;; 6 Otitis media history not significant
| Sub-sample of larger prospective study of persistent otitis media with effusion | | | | 1 Birth weight <5 lb; 2 Small for gestational age; 3 History of neonatal asphyxia or serious illness; 4 Multiple birth; 5 Foster care or adopted; 6 Mother <18 years old; 7 Mother ill or dead; 8 Mother known to abuse drugs or alcohol or too limited to give informed consent or adhere to protocol; 9 Other than English spoken in home; 10 Other sibling was participating in study; 11 Parents planned to move away in 5 years | | | Controls=241 (not meeting above criteria) | | Aggregated risk factors, low maternal education, male sex, positive family history, OR=7.71 (2.62–22.74)
Cantwell, 1985 | 600 | Cross sectional | Multiple types of speech and language disorders | Large community speech and hearing clinic in Los Angeles, CA area | [underlined: Exclusion:] | 20.4 – 190.8 (median 58.8) | Standardized tests for speech and language with informal methods for children who were untestable; includes psychiatric measures, interviewing parents and child, and behavior rating scales | 397 cases | Psychiatric syndromes and their associations with speech and language disorders | No unique psychiatric syndrome was associated with speech and language disorders
| | | | | 1 >16 years; 2 Significant hearing impairment
Choudhury, 2003 | 136 from 112 families | Case control | Specific language impairment | New York, NY, Newark, NJ, and surrounding New Jersey suburbs; obstetric and pediatric practices and samples of several pooled longitudinal studies | [underlined: Inclusion:] | 36 | Parent questionnaire for demographic information and family medical history; test results of affected family member (proband). Subset of cases were administered a battery of standardized language and cognitive assessments (Preschool Language Scale-3, 2 subtests of Clinical Evaluation of Language Fundamentals-Preschool, sentence structure and word structure, Stanford-Biner Intelligence Scale, 4th edition) | Positive family history=42 (37 families) | 1 Gender; 2 Differences between family history groups for parental age, education, socioeconomic status, number and gender of children.; 3 Medical disorders | [underlined: In family aggregation study:] Males were more affected (p<0.005), sons 41%, fathers 18%, daughters 16%, mothers 11%. Specific language impairment males were more likely to have an affected sibling (p<0.05). Male probands had more brothers (1.45 brothers vs 0.05 sisters) and female probands had more sisters (1.25 sisters vs. 0.25 brothers; p<0.05). No association of gender of impaired parent and number of impaired children (p>0.5) but specific language impairment mothers had more girls than expected (p<0.05)
| | | | | 1 Family member had at least 1 affected child or parent with language scores at least 1 standard deviation below age appropriate mean; 2 Standardized test of general cognitive ability was within normal range | | | Negative family history=94 (75 families) | | [underlined: Comparison of positive vs negative family history:] Children with positive family history tended to have more children in family and older parents, but no differences in socioeconomic status and parent education. Children with positive family history were more likely to report family history of autoimmune diseases (p<0.001) but not asthma.
| | | | | [underlined: Exclusion:] | | | 92 children received standard language tests (32 with positive and 60 with negative family histories)
| | | | | 1 Prematurity, low birth weight; 2 Pervasive developmental disorder or autism diagnosed in family proband, or Attention deficit disorder; 3 Hearing loss; 4 Neurological disorder or oral motor impairment
Singer, 2001 | 263 | Case control | Language | Level 3 NICU in the Cleveland, OH region | [underlined: Inclusion:] | 36 (corrected for prematurity) | Standardized testing at facility including Bayley Scales of Infant Development II and Communication Domain Subscale of Battelle Developmental Inventory, and demographic information from hospital chart | 98 cases (VLBW/Bronchopulmonary Dysplasia); 70 controls (non Bronchopulmonary Dysplasia), 95 term controls; all were patients in the NICU as newborns | 1 Bronchopulmonary dysplasia; 2 Patent ductus arteriosis | Bronchopulmonary dysplasia was associated with lower language score (p<0.005 on Battelle); especially receptive language (p<0.02) after other controlling for other factors Patent ductus arteriosis was associated with socioeconomic status, neurological risk, and minority race (all p<0.001)
| | | | | Cases
| | | | | 1 Preterm (<1500 grams); 2 >28 days with x-ray findings of chronic lung disease without neurological problems and not socially disadvantaged (Hollingshead class IV and V)
| | | | | Controls
| | | | | 1 The next born VLBW infant without bronchopulmonary dysplasia of same race social status; 2 Term infants from newborn nurseries; next born of same race and social status
| | | | | [underlined: Exclusion:]
| | | | | 1 Major congenital malformations; 2 Drug exposure; 3 Mother with major psychiatric or physical illness; 4 HIV or mental retardation; 5 Live >2 hours drive from facility
Tallal, 1989 | 150 | Case control | Language | San Diego, CA; referred from school, clinics, and private professionals serving language-impaired children | [underlined: Inclusion:] | 48 – 59 | Parent questionnaire was used for the study, although a sample of cases and controls was taken after assessment of larger group. | 76 cases (54 boys and 22 girls) | 1 Mothers, fathers, or siblings with history of language or learning problems; 2 Parental history of below average school achievement to 8th grade (reading, writing, or kept back a grade through 8th grade) | Mothers of impaired children were more likely to have a history of language problems (p<0.02), more likely kept back in school (p<0.03), more likely to be poor readers (p<0.0001), and writers (p<0.0001) in school. More mothers of affected children met criteria for affected (p<0.05). Fathers of cases were more likely to report being kept back (p<0.03) and more often met criteria for affected (p<0.02). Siblings of cases were more likely to be affected (p<0.05), and frequency of sibling impairment was not significantly influenced by number of parents affected. Impaired children were more likely to have a positive family history (at least 1 first-degree relative affected; p<0.002)
| | | | | 1 Aged 48–59 months; 2 Nonverbal performance IQ of 85 or better on the Leiter International Performance Scale; 3 Mean language age at least 1 year below both performance mental age and chronologic age; 4 Normal hearing and no oral, structural, or motor impairments affecting nonspeech movement of articulators; 5 English language background only; no nonstandard dialectical usage or other language; 6 No autism; 7 No neurological disorders; 8 Data could be collected from both parents | | | 54 controls (27 boys and 27 girls)
Tomblin, 1991 | 662 | Case series | Speech and language | Pediatric offices in Iowa | [underlined: Inclusion:] | 30 – 60 | Developmental testing by pediatrician as part of longitudinal study. Parent questionnaire included parent concerns, history of hearing impairment, history of speech/language delay, developmental issues, and questions from the Early Language Milestone Scale, Preschool Development Inventory, and the Minnesota Child Development Inventory | Part of a larger cohort in a longitudinal study | 1 Sex; 2 Birth order; 3 Birth weight; 4 Father's education level; 5 Mother's education level; 6 Infant risk score (at risk; question of risk; no risk); a Birth events; b Family history of speech/language problem; c Family history of hearing loss | 1 Male (p=0.043); 2 Later born (p<0.0001); 3 No difference for mean weight; 4 Lower father's education level (p<0.029); 5 No difference for mother's education level; 6 Poor communication group rated at risk or question of risk as infant (p<0.0001); (sensitivity of risk score system=0.55, specificity=0.76)
| | | | | 1 Not at risk for neurodevelopmental difficulties; 2 Could get questionnaire back; 3 Patient at one of 16 participating pediatricians' offices
Tomblin, 1997 | 1,102 | Case control | Speech and language | Metropolitan areas in Iowa or Western Illinois | [underlined: Inclusion:] | Kindergarten age (otherwise not specified) | Standardized language assessment battery and telephone survey using risk questionnaire; interviewers were blinded. | 177 cases | 1 Parents' socio-demographics; 2 Pre and postnatal exposures of parent (infections, hypertension, drugs, immune system disorders, adverse health behaviors, work related exposures); 3 Pregnancy conditions | Significant associations: younger mothers (p<0.005); fathers with learning problems (speech, learning or mental retardation) (p<0.05); both parents with lower education status (p<0.05).
| | | | | 1 Monolingual English speakers; 2 Consent obtained; 3 Failed language test for cases; 4 Age appropriate language for controls who also had normal hearing; 5 Age appropriate nonverbal language Matched with cases on gender & residential variables | | | 925 controls | | Maternal exposures had no significant differences (maternal smoking did but not when adjusted for education level). Paternal exposures significantly higher (smoking even when adjusted for education level).
| | | | | [underlined: Exclusion:] | | | | | Not associated with low birth weight, type of delivery, labor history of delivery complications.
| | | | | 1 Sensory impairment; 2 Mental retardation or autism; 3 Cerebral palsy; 4 Severe head injury; 5 Visual impairment | | | | | Less time breastfeeding (p<0.05)
Whitehurst, 1991 | 117 | Prospective cohort | Expressive language delay | Long Island, NY | Cases met criteria of expressive language delay (expressive language >2.33 standard deviations below mean, and standard scores of at least 85 for receptive language and cognitive abilities) | 24 – 38 | Recruited through advertisements in local papers; tested on standardized tests; language sample audio taped; hearing information obtained; medical records reviewed; parental questionnaire regarding family history | 62 cases | Family history of late talking, speech problems, or school problems | No strong familial component found; no differences for separate analyses for male and female relatives except mothers of cases more likely to have been late talking (p=0.049). 85% of cases were boys
| | | | | Controls were matched to cases on age, sex, SES status, and scored in the normal range on all 3 standardized tests | | | 55 controls
Non-English Language Studies
Fox, 2002 (Germany) | 113 | Cross sectional | Speech | Northern Germany from 2 private practices for speech and language therapy and 13 kindergartens | [underlined: Inclusion:] | Cases 32.4 – 86.4 | Direct testing with speech instruments for children and parent questionnaire on child's developmental history | 65 cases | 1 Pre and perinatal problems; 2 Hearing problems caused by fluctuating hearing abilities, acute middle ear infections, or a high number of further ENT problems; 3 Sucking habits; 4 Positive family history for speech and/or language difficulties | Controlling for age and gender:
| | | | | 1 German as native language; 2 Monolingual living in northern Germany study area | Control 40.8 – 73.2 | | 48 controls | | 1 Birth difficulties (p=0.020); 2 ENT history (p=0.54); 3 Sucking habits (p =0.007); 4 Positive family history (p=0.020)
| | | | | [underlined: Exclusion:]
| | | | | 1 More general language problem; 2 Sensory impairment, organic motor disorder, craniofacial anatomical anomaly or intellectual impairment; 3 Bilingualism; 4 Previous speech intervention; 5 Only articulation disorder
Klein, 1986 (Israel) | 72 | Concurrent comparison group | Vocabulary | 15 kindergarten classes in predominantly middle-class urban area | [underlined: Inclusion:] | 53 – 69 | Teachers picked a child in each of 3 categories (easy, difficult, or slow-to-warm up), corroborated by parents on behavior questionnaire, and assessed cognitive performance on 3 types of tasks (vocabulary, abstract reasoning, and immediate sequential memory) using standardized tests. Vocabulary from Peabody picture Vocabulary Test and from the Wechsler Preschool and Primary Scale of Intelligence-Revised | Easy: 12 boys, 12 girls | 1 Temperament (easy, difficult, or slow-to warm up) | No differences were found between temperament groups on vocabulary tests, and no difference between boys and girls.
| | | | | 1 Teacher identified children who were easy, difficult, and slow-to-warm-up; 2 Parent confirmed temperament by Behavioral Style Questionnaire (BSQ) | | | Difficult: 14 boys, 10 girls
| | | | | | | | Slow-to-warm-up: 14 boys, 10 girls
Kloth, 1995 (Netherlands) | 93 | Case control | Stuttering | Referred by area pediatricians, members of the Dutch Association of Stutters, and speech-language pathologists | [underlined: Inclusion:] | 23 – 58 | Dysfluency questionnaire and video recorded sessions were transcribed and random sections were reviewed independently by 2 judges | Subjects were children of parents who stutter or had a history of stuttering, none of the 93 children stuttered at the beginning of the study. | 1 Communicative style, speaking rate, and language complexity of the mothers | No significant difference in the number of mothers who stutter in the 2 groups. Mothers of stutterers had significantly shorter mean length utterances (p<0.01) than mothers of nonstutterers. Speaking style and rate were not significantly different between groups
| | | | | 1 One or both parents stutters; 2 Children were reported to have normal intelligence; 3 Demonstrated to function within age-related normal range for expressive and receptive language; 4 Passed audiometric test | | | 26 cases: children who developed stuttering during the year under study
| | | | | | | | 67 controls
Lyytinen, 2001 (Finland) | 200 | Prospective cohort study | Speech and language | Maternity clinics in central Finland from 4/1/93 to 7/31/96 | [underlined: Inclusion:] | 0 – 54 | Parents and relatives who reported reading problems were individually assessed for reading and related skills; serial assessments of the child from birth to 4.5 years | 107 with familial risk of dyslexia | Family history of dyslexia | The biological (family) risk for dyslexia is still a significant predictor of language development at 5 years even after taking into account the earlier language achievements, environmental factors, and a significant number of preschool predictors of reading skills (p<0.05)
| | | | | 1 Parents IQ >80; 2 Parents with three or more scores at least one SD below norm on several reading or spelling measures | | | 93 without familial risk for dyslexia
Peters, 1997 (Netherlands) | 946 | Prospective cohort | Language and educational attainment | Birth cohort in Nijmegen, Netherlands | [underlined: Inclusion:] | 84 – 96 | Regular tympanograms and age 7–8 years full audiological and tests of language; questionnaire to teacher | 2X2 design according to level of subject's risk (high or low) and the presence of otitis media or control (no otitis) | 1 With or without history of otitis media | Significant associations: Low parental education level and no otitis were associated with general language delay (p<0.01); having otitis had no additional negative effect. No effect of sex with or without otitis on general language. Preterm birth/LBW and otitis had no interaction for general language or phonological ability, same risk factors in control group had poorer scores for phonological ability (p<0.05) and non-verbal intelligence (p<0.05), but no effect on general language. Language other than Dutch as a first language is a risk factor for language (p<0.0001), but no interaction effects with otitis on language. The combined effect of early bilateral otitis and other risk factors is only small
| | | | | 1 Either bilateral B tympanograms on two consecutive occasions between 2 and 4 years old or never had a bilateral B tympanogram | | | | Additional risk factors
| | | | | | | | | 1 Low educational level for both parents; 2 Male sex; 3 Low non-verbal intelligence; 4 Preterm birth and LBW; 5 Dutch as a second language
Weindrich, 2000 (Germany) | 320 | Prospective cohort | Receptive, expressive language, and articulation in the 4.5 year old and reading and spelling at age 8 years | Infants at birth from a hospital in Germany | [underlined: Inclusion:] | Tested at 54 and 96 | Direct testing | Part of a larger cohort in a longitudinal study | Biologic risk: birth weight, gestational age, nonelective surgical delivery, toxemia, neonatal asphyxia, neonatal complications | Biologic risk is most strongly associated with language development of the 4.5 year olds in the clinical group (p≤ 0.05), no such effect was significant at age 8 for spelling/reading or language. Psychosocial risk were more often diagnosed with language disorder than the nonrisk group (delay p≤ 0.01 and clinical p≤ 0.05). Preterm labor/birth, gestosis, and VLBW were of significance and almost all the psychosocial risk factors except marital disharmony and lack of social support were important
| | | | | 1 First born singletons of German speaking parents; 2 Passed hearing screening | | | | Psychological risk: low parental education level, overcrowding, parental psychiatric disorder, history of broken home or delinquency, marital discord, early parenthood, one-parent family, unwanted pregnancy, poor social integration and support of parents, severe chronic difficulties, poor coping skills of a parent.
| | | | | [underlined: Exclusion:] | | | | Child was assigned as nonrisk, moderate risk, or high risk in each of these two categories.
| | | | | 1 Severe physical handicaps, obvious genetic defects or metabolic diseases; 2 Severe motor or mental handicaps or autism
Yliherva, 2001 (Finland) | 8,370 | Prospective cohort | Speech, language, learning, motor abilities | Finland, two northern provinces, included 99% of pregnant women in 1985 -1986 | [underlined: Inclusion:] | 96 | Structured questionnaire of mothers during pregnancy and at age 7 years for socio-demographic data; questionnaire of hospital staff and midwives; parent and teacher questionnaire at age 8 years on speech, language, learning and motor abilities | 9,362 participated at birth and 8,370 responded for evaluation at 8 years | 1 Neonatal risk factors; 2 Birth weight (<1500 g, 1500–2499 g, ≥2500 g); 3 Gestational age (>32 wk, 32–36 wk, >37 wk); 4 SGA; 5 Mother's age; 6 Mother's education; marital status and changes over time; 7 Number of children in home; 8 Place of residence | LBW (<2500 g) had poorer speech at 8 years (p=0.001) and more confusion in discriminating between sounds (p=0.001). LBW girls had poorer speech than normal weight girls (p=0.001), and LBW boys confused certain sounds more than normal boys (p=0.004). LBW boys had the highest prevalence of problems in speech, and LBW girls performed equally well compared with the NBW boys. LBW children had more difficulties following instructions concerning activities (p=0.028), and more difficulties than normal children in discriminating separate sounds from background noise (p=0.018), LBW boys especially (p=0.020).
| | | | | 1 Cohort of all children born in the determined area between July 1, 1985 and June 30, 1986; 2 Mothers agreed to participate; 3 Children still living in area that can be contacted | | | | | [underlined: Multrivariate logistic regression:] Children weighing 1500–2499 g were at greatest risk when adjusted for sociodemographic information. Neonatal risk, VLBW (<1500 g), problems in understanding linguistic concepts, hearing impairment, and male gender highly increased risk for speech and language delay. Four or more children in the family, and reconstructed family status were associated with problems in speech perception and understanding.
| | | | | | | | | | [underlined: Linguistic concepts:] Small for gestational age increased adjusted risk for problems in speech production (p=0.001), speech perception (p=0.006) and linguistic concepts (p=0.022). Preterm birth without the neonatal risk factors increased problems in speech perception (p=0.015)