# Appendix 3. Inclusion/Exclusion Criteria By Key Question

## Key Question 2 (Screening)

Include | RCT with speech and language measures.
| Cohort, case control, or other type of observational study with speech and language measures
| Review or meta-analysis with relevant information.
Exclude | Sample size too small (N<20).
| Case report.
| Foreign language.
| Test not relevant to the primary care setting (e.g., administered by specialist only).
| Description of instrument only, no data.
| Previously diagnosed subjects (unless a comparison group).
| Wrong format (opinion, letter, editorial etc.).
| Wrong age group (>5 years old).
| Related to topic but does not address key question.
| No relevance to topic.

## Key Question 2b (Risk Factors)

Include | RCT, cohort, case control, cross-sectional, descriptive, or other type of observational study with speech and language measures.
| Review or meta-analysis with relevant information.
Exclude | Sample size too small (N<20).
| Case report.
| Foreign language.
| Focus on another diagnosis (ADHD, autism, etc.).
| Wrong format (opinion, letter, editorial etc.).
| Wrong age group (>5 years old).
| Related to topic but does not address key question.
| No relevance to topic.

## Key Question 3 and 8 (Adverse Effects)

Include | RCT, cohort, case control, or other type of observational study with speech and language measures.
| Review or meta-analysis with relevant information.
| Adverse impact of speech and language delay diagnosis and treatment on the child (any age).
| Adverse impact of speech and language delay diagnosis and treatment on family or others.
Exclude | Sample size too small (N<20).
| Case report.
| Foreign language.
| Not relevant to the primary care setting.
| Description only, no data.
| Wrong format (opinion, letter, editorial etc.).
| Wrong age group (>5 years old).
| Related to topic but does not address key question.
| No relevance to topic.

## Key Question 4 (Surveillance)

Include | RCT with speech and language measures.
| Cohort, case control, or other type of observational study with speech and language measures.
| Review or meta-analysis with relevant information.
Exclude | Sample size too small (N<20).
| Case report.
| Foreign language.
| Test not relevant to the primary care setting (e.g., administered by specialist only).
| Description only, no data.
| Previously diagnosed subjects.
| Wrong format (opinion, letter, editorial etc.).
| Wrong age group (>5 years old).
| Related to topic but does not address key question.
| No relevance to topic.

## Key Question 5, 6, and 7 (Interventions and Outcomes)

Include | RCT with appropriate speech and language outcomes.
| Cohort, case control, or other type of observational study with appropriate speech and language outcomes.
| Review or meta-analysis with relevant information.
Exclude | Case study.
| Foreign language.
| Description of instrument or intervention only, no data.
| Focus on another diagnosis (ADHD, autism, etc.).
| Wrong format (opinion, letter, editorial etc.).
| Related to topic but does not address key question.
| No relevance to topic.