# Appendix 2. Search Strategies

## Search Terms

Appropriate terms were selected in conjunction with a medical research librarian and experts in the field, and individual search strategies were created to retrieve the literature pertaining to communication disorders and the following concepts: children age 5 years and younger, primary health care practitioners, pediatricians, risk factors and risk assessment, psychological tests, diagnostic techniques and procedures, adverse effects, outcomes, quality of life, and epidemiological studies.

## MEDLINE - 1966 to November 19, 2004

### Screening

1 exp Communication Disorders/cl, di [Classification, Diagnosis]
2 exp Psychological Tests/
3 exp “Diagnostic Techniques and Procedures”/
4 exp mass screening/
5 1 and (2 or 3 or 4)
6 limit 5 to (english language and (all infant <birth to 23 months> or preschool child <2 to 5 years>))
7 limit 5 to (abstracts and (all infant <birth to 23 months> or preschool child <2 to 5 years>))
8 6 or 7
9 exp RISK/
10 1 and 9
11 limit 10 to (english language and (all infant <birth to 23 months> or preschool child <2 to 5 years>))
12 limit 10 to (abstracts and (all infant <birth to 23 months> or preschool child <2 to 5 years>))
13 11 or 12
14 primary care.mp. or exp Primary Health Care/
15 family physicians.mp. or exp Physicians, Family/
16 Pediatrics/ or pediatrician$.mp.
17 exp child health services/ or exp preventive health services/
18 14 or 15 or 16 or 17
19 1 and 18
20 limit 19 to (english language and (all infant <birth to 23 months> or preschool child <2 to 5 years>))
21 limit 19 to (abstracts and (all infant <birth to 23 months> or preschool child <2 to 5 years>))
22 20 or 21
23 exp “Sensitivity and Specificity”/
24 exp Diagnostic Errors/
25 diagnosis, differential/
26 23 or 24 or 25
27 1 and 26
28 limit 27 to (english language and all child <0 to 18 years>)
29 limit 27 to (abstracts and all child <0 to 18 years>)
30 28 or 29
31 limit 1 to (all child <0 to 18 years> and (controlled clinical trial or guideline or meta analysis or multicenter study or practice guideline or randomized controlled trial))
32 exp epidemiologic studies/
33 1 and 32
34 limit 33 to (english language and all child <0 to 18 years>)
35 limit 33 to (abstracts and all child <0 to 18 years>)
36 34 or 35
37 31 or 36

### Adverse Effects

1 exp Communication Disorders/
2 (adverse effect$ or harm$ or stigma$).mp. or exp stress, psychological/et or exp life change events/ or exp prejudice/ or exp stereotyping/ or exp self concept/
3 exp diagnostic errors/
4 2 or 3
5 1 and 4
6 limit 5 to (english language and all child <0 to 18 years>)

### Interventions/Outcomes

1 exp Communication Disorders/nu, dt, pc, rh, su, th [Nursing, Drug Therapy, Prevention & Control, Rehabilitation, Surgery, Therapy]
2 Cost of Illness/
3 exp Quality of Life/
4 exp EMPLOYMENT/
5 exp Psychology, Industrial/
6 exp Family Relations/
7 exp family/ or exp interpersonal relations/
8 exp Educational Status/ or exp Educational Measurement/
9 exp Motivation/
10 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11 1 and 10
12 limit 11 to (english language and all child <0 to 18 years>)
13 exp “OUTCOME AND PROCESS ASSESSMENT (HEALTH CARE)”/
14 1 and 13
15 limit 14 to (english language and all child <0 to 18 years>)
16 Comparative Study/
17 exp Evaluation Studies/
18 exp Epidemiologic Studies/
19 16 or 17 or 18
20 1 and 19
21 limit 20 to (english language and all child <0 to 18 years>)
22 limit 1 to (english language and all child <0 to 18 years> and (clinical trial or guideline or meta analysis or multicenter study or practice guideline or review))
23 12 or 15 or 21 or 22

## PsycINFO - 1974 to November 19, 2004

### Screening

1 exp Communication Disorders/
2 exp Diagnosis/
3 1 and 2
4 limit 3 to (english language and (120 neonatal <birth to age 1 mo> or 140 infancy <age 2 to 23 mo> or 160 preschool age <age 2 to 5 yrs>))
5 exp RISK PERCEPTION/ or exp RISK ANALYSIS/ or exp RISK MANAGEMENT/ or exp AT RISK POPULATIONS/ or exp RISK FACTORS/
6 1 and 5
7 limit 6 to (english language and (120 neonatal <birth to age 1 mo> or 140 infancy <age 2 to 23 mo> or 160 preschool age <age 2 to 5 yrs>))
8 exp Primary Health Care/ or primary care.mp.
9 family physician$.mp. or exp Family Physicians/
10 pediatrician$.mp. or exp PEDIATRICIANS/
11 pediatrics.mp. or exp PEDIATRICS/
12 public health services/
13 8 or 9 or 10 or 11 or 12
14 1 and 13
15 limit 14 to (english language and (120 neonatal <birth to age 1 mo> or 140 infancy <age 2 to 23 mo> or 160 preschool age <age 2 to 5 yrs>))
16 exp Differential Diagnosis/
17 exp TEST VALIDITY/ or exp STATISTICAL VALIDITY/
18 1 and 17
19 16 or 17
20 1 and 19
21 limit 20 to (english language and (120 neonatal <birth to age 1 mo> or 140 infancy <age 2 to 23 mo> or 160 preschool age <age 2 to 5 yrs>))
22 ((case adj control$) or cohort$ or longitudinal$ or ((prospective$ or (follow adj up)) adj5 (study or studies))).mp. [mp=title, abstract, heading word, table of contents, key concepts]
23 exp experimental design/
24 22 or 23
25 1 and 24
26 limit 25 to (english language and (120 neonatal <birth to age 1 mo> or 140 infancy <age 2 to 23 mo> or 160 preschool age <age 2 to 5 yrs>))

### Adverse Effects

1 exp communication disorders/
2 exp psychological stress/
3 coping behavior/
4 exp Stereotyped Attitudes/
5 exp PREJUDICE/
6 exp Errors/
7 exp self concept/
8 (adverse effect$ or harm$ or stigma$ or stereotyp$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
9 2 or 3 or 4 or 5 or 6 or 7 or 8
10 1 and 9
11 limit 10 to (english language and (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>))

## CINAHL - 1982 to November 19, 2004

### Screening

1 exp Communicative Disorders/cl, di, ev [Classification, Diagnosis, Evaluation]
2 exp Psychological Tests/
3 (diagnostic techniques and procedures).mp. [mp=title, cinahl subject headings, abstract, instrumentation]
4 functional assessment/ or health screening/ or exp “speech and language assessment”/
5 2 or 3 or 4
6 1 and 5
7 limit 6 to (english and (infant <1 to 23 months> or preschool child <2 to 5 years>))
8 exp RISK ASSESSMENT/ or exp RISK FACTORS/
9 risk$.mp.
10 8 or 9
11 1 and 10
12 limit 11 to (english and (infant <1 to 23 months> or preschool child <2 to 5 years>))
13 primary care.mp. or exp Primary Health Care/
14 family physicians.mp. or exp Physicians, Family/
15 pediatrician$.mp. or exp Pediatrics/
16 exp Pediatric Care/ or pediatrician$.mp. or exp Pediatrics/
17 exp Child Health Services/
18 Preventive Health Care/
19 13 or 14 or 15 or 16 or 17 or 18
20 1 and 19
21 limit 20 to (english and (infant <1 to 23 months> or preschool child <2 to 5 years>))
22 exp “Sensitivity and Specificity”/
23 exp Diagnostic Errors/
24 exp Diagnosis, Differential/
25 22 or 23 or 24
26 1 and 25
27 limit 26 to (english and (infant <1 to 23 months> or preschool child <2 to 5 years>))
28 exp Study Design/
29 1 and 28
30 limit 29 to (english and (infant <1 to 23 months> or preschool child <2 to 5 years>))
31 12 or 21 or 27 or 30

### Adverse Effects

1 exp Communicative Disorders/
2 exp Stress, Psychological/
3 exp Life Change Events/
4 exp PREJUDICE/
5 exp STEREOTYPING/
6 exp Self Concept/
7 exp diagnostic errors/
8 (adverse effect$ or harm$ or stigma$ or stereotyp$).mp. [mp=title, cinahl subject headings, abstract, instrumentation]
9 2 or 3 or 4 or 5 or 6 or 7 or 8
10 1 and 9
11 limit 10 to (english and (infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>))