# Appendix 1. Reviewers

## Expert Reviewers

- Robert Buckendorf, PhD
- Department of Child Development Speech/Auditory
- Oregon Health & Science University
- Portland, OR

- Charles Homer, MD, MPH
- National Initiative for Children's Healthcare Quality
- Cambridge, MA

- James Law, PhD
- Department of Language and Communication Science
- City University
- London, UK

- Fredrick Palmer, MD
- University of Tennessee, Health Science Center
- Memphis, TN

- Brian Rogers, MD
- Child Development and Rehabilitation Center
- Oregon Health & Science University
- Portland, OR

- Bruce K. Shapiro, M.D.
- Kennedy Krieger Institute
- Baltimore, MD

## Professional Organizations and Federal Agencies

American Academy of Family Physicians

American Academy of Pediatrics

American Speech-Language-Hearing Association

Centers for Disease Control and Prevention

National Institutes of Health

Society of Researchers in Child Development

Society for Developmental and Behavioral Pediatrics