# Appendixes

Appendix 1. Reviewers

Appendix 2. Search Strategies

Appendix 3. Inclusion/Exclusion Criteria By Key Question

Appendix 4. USPSTF Quality Rating Criteria

Appendix 6. Evidence Table: Studies of Risk Factors

Appendix 7. Descriptions of Instruments Used in Studies

Appendix 8. Quality Ratings of Screening Instrument Studies

Appendix 9. Evidence Table: Randomized Controlled Trials of Interventions

Appendix 10. Quality Ratings of Intervention Studies