# Appendix

Appendix Table 1. Prevalence of Iron Deficiency - United States, National Health and Nutrition Examination surveys, 1988-1994 and 1999-2000*

Sex/Age group (yrs) | 1988-1994 | | | 1999-2000
| No. | % | (95% CI^†^) | No. | % | (95% CI)
Both Sexes
1–2 | 1339 | 9 | (6–11) | 319 | 7 | (3–11)
3–5 | 2334 | 3 | (2–4) | 363 | 5 | (2–7)
6–11 | 2813 | 2 | (1–3) | 882 | 4 | (1–7)
Males
12–15 | 691 | 1^‡§^ | (0.1–2) | 547 | 5 | (2–8)
16–69 | 6635 | 1 | (0.6–1) | 2084 | 2 | (1–3)
70 | 1437 | 4 | (2–3) | 381 | 3^‡^ | (2–7)
Females║
12–49 | 5982 | 11 | (10–12) | 1950 | 12 | (10–14)
12–15 | 786 | 9 | (6–12) | 535 | 9 | (5–12)
16–69 | 700 | 11 | (7–14) | 466 | 16 | (10–22)
20–49 | 4495 | 11 | (10–13) | 949 | 12 | (10–16)
White, non-Hispanic | 1827 | 8 | (7–9) | 573 | 10 | (7–13)
Black, non-Hispanic | 2021 | 15 | (13–17) | 498 | 19 | (14–24)
Mexican American | 1845 | 19 | (17–21) | 709 | 22 | (17–27)
50–69 | 2034 | 5 | (4–7) | 611 | 9 | (5–12)
70 | 1630 | 7 | (5–8) | 394 | 6 | (4–9)

Data from MMWR 2002. ^10^

* All racial/ethnic groups except where noted.

† Confidence interval.

‡ Unreliable; relative standard error (i.e., standard error/prevalence estimate) is > 30%.

§ P<0.05 for comparison between surveys within age and sex category.

║ Non-pregnant only.

Evidence Table 1. Iron supplementation trials

Trial | Setting | Subjects | Age (mos.) | N | Design Characteristics | Treatment (duration) | Control | Follow-up Assessment | Time (mos.) | Results
Panel 1. Supplementation in developing countries
Lozoff, 2003 ^63^ (Formula donated by maker) | Four working-class communities on the outskirts of Santiago, Chile | Breastfed infants, weaned after 6 months. | 6 | 1657 | Partly randomized. | High-iron formula (12 mg/L) or low-iron formula (2.3 mg/L) | No-iron-added cow's milk plus multivitamin without iron (n=584) | BSIS, Fagan Test of Infant Intelligence. | 12 | No difference in PDI or MDI scores. Longer looking time in controls (1.39±0.02 seconds vs. 1.46±0.04 s)
| | | | | Blinding unclear.
| | | | | Some baseline differences in compared groups.
| | | | | Outcome assessment was incomplete.
Lind, 2004 ^64^ (Industry) | Purworejo, Central Java, Indonesia (malnutrition) | 680 healthy term infants. | 6 | 680 | Randomized. | Iron or Zinc plus Iron. | Zinc alone or placebo. | BSIS. | 12 | PDI 106 ± 11 vs. placebo group 103 ± 10.8.
| | | | | Probably blinded.
| | | | | 655/680 analyzed.
Panel 2. Supplementation in developed countries
Moffatt, 1994 ^60^ | Low-income, high-risk urban hospital clinic, Canada | Healthy infants | <6 | 283 | DBRCT. | Iron-fortified formula. | Regular formula. | BSID. | 15 | Better psychomotor scores (+6.4) at 9 and 12 months but not at 15 months; no differences in cognition or behavior.
| | | | | High dropout rate.
| | | | | 20.5% dropped out before any outcome data were gathered; 225, 204, 186, and 154 remained at 6-, 9-, 12-, and 15-month assessments.
Williams, 1999 ^66^ | Low-income, high-risk area neighborhood clinic, Birmingham, England. | Term infants on cow's milk. 14% were anemic at baseline. | 6–8 | 100 | SBRCT. | Formula for 18 mos., then cow's milk until 24 mos. | Cash payment sufficient to buy 500 ml of cow's milk daily for 24 mos. | Griffith's. | 18, 24 | No difference at 18 months. At 24 months, + difference in global developmental quotient (+5.4 points).
| | | | | Fair quality.
| | | | | 85/100 included in analysis due in part to exclusions after randomization.
Morley, 1999 ^59^ | Average-risk area, Leicester, Norwich, and Nottingham, England | Healthy full-term infants on pasteurized cow's milk. | 9 | 493 | SBRCT. | Formula containing 0.9 mg/liter iron or formula containing 1.2 mg/liter iron. | Continue on cows' milk (estimated to contain 0.05 mg iron/liter). | BSID. | 18 | No differences.
| | | | | Fair-quality.
| | | | | 428/493 included in analysis.
Friel, 2003 ^67^ | Average-risk area, Newfoundland, Canada | Healthy, breastfed infants | 1 | 77 | DBRCT. | Oral iron syrup from 1 to 6 mos. of age. | Placebo as syrup alone. | BSID. | 13 | PDI (100 ± 12 vs. 93 ± 9; normal range 85 to 115) MDI scores did not differ. Trend (P =.07) for improved visual acuity.
| | | | | Fair-to-poor; small, underpowered study with a high dropout rate.
| | | | | 77, 56, 51, and 44 infants were seen at 1, 3.5, 6, and 12 mos.
Metallinos-Katsaras, 2004 ^68^ | Low-income, high-risk area day-care centers in Athens, Greece. | Healthy children except for low iron intake. | 3–4 years | 49 | RCT. | MV for 2 mos., then MV plus either 15mg iron in the form of ferrous fumarate or placebo for 2 mos. | Placebo. | Reaction time, a continuous performance task (CPT), and 3 oddity learning (OL) tasks. | 2 | In ITT analysis, for “suspected anemic” subjects only, treatment improved reaction time (P<0.05), speed of discrimination P<0.05), and CPT efficiency (P<0.10).
| | | | | Fair quality.
| | | | | Allocation concealment, blinding not discussed.

BSID = Bayley Scales of Infant Development, DBRCT = Double-blinded randomized controlled trial, ITT = Intention to treat, MDI = Mental Development Index, MV = Multivitamin, PDI = Psychomotor Development Index, RCT = Randomized controlled trial, SBRCT = Single-blinded randomized controlled trial