# References

1 U.S. Preventive Services Task Force. Routine iron supplementation during pregnancy. JAMA. 1993;270:2848-2854. [pmid: 8133626].
2 U. S. Preventive Services Task Force. Screening for Iron Deficiency Anemia-Including Iron Prophylaxis. Guide to Clinical Preventive Services, Second Edition. Baltimore: Willliams and Wilkins; 1996.
3 Conway A, Hincliffe R, Earland J, Anderson L. Measurement of Haemoglobin using single drops of skin puncture blood: is precision acceptable?. J Clin Path. 1998;51:248-250. [pmid: 9659272].
4 Looker A, Dallman P, Carroll M, et al. Prevalence of Iron deficiency in the United States. JAMA. 1997;277:973-976. [pmid: 9091669].
5 Recommendations to prevent and control iron deficiency in the United States. Centers for Disease Control and Prevention. Morbidity & Mortality Weekly Report. Recommendations & Reports. 1998;47(RR-3):1–29.
6 Domellof M, Dewey KG, Lonnerdal B, Cohen RJ, Hernell O. The diagnostic criteria for iron deficiency in infants should be reevaluated. Journal of Nutrition. 2002;132(12):3680-3686. [pmid: 12468607].
7 Wright C, Kelly J, Trail A, Parkinson K, Summerfield G. The diagnosis of borderline iron deficiency: results of a therapeutic trial. Arch. Dis. Child. 2004;89:1028-1031. [pmid: 15499056].
8 White K. Anemia Is a Poor Predictor of Iron Deficiency Among Toddlers in the United States: For Heme the Bell Tolls. Pediatrics. 2005;115(2):315-320. [pmid: 15687438].
9 Frith-Terhune AL, Cogswell ME, Khan LK, Will JC, Ramakrishnan U. Iron deficiency anemia: higher prevalence in Mexican American than in non-Hispanic white females in the third National Health and Nutrition Examination Survey, 1988-1994. Am. J. Clinical Nutrition. 2000;72(4):963-968. [pmid: 11010938].
10 Iron Deficiency — United States, 1999-2000. MMWR. 2002;51(40):897–899
11 Sherriff A, Emond A, Hawkins N, Golding J. the ALSPAC Children in Focus Study Team. Haemoglobin and ferritin concentrations in children aged 12 and 18 months. Arch. Dis. Child. 1999;80(2):153-157. [pmid: 10325731].
12 Pilch SM, Senti FR, eds. Assessment of the iron nutritional status of the US population based on data collected in the second National Health and Nutrition Examination Survey, 1976-1980. Rockville, MD: Life Sciences Research Office, Federation of American Societies for Experimental Biology; 1984.
13 Scholl TO. Iron status during pregnancy: setting the stage for mother and infant. Am J Clin Nutr. 2005;81(5):1218S-1222. [pmid: 15883455].
14 Sherriff A, Emond A, Bell JC, Golding J. Team AS. Should infants be screened for anaemia? A prospective study investigating the relation between haemoglobin at 8, 12, and 18 months and development at 18 months. Archives of Disease in Childhood. 2001;84(6):480-485. [pmid: 11369562].
15 Sadler S. Iron deficiency in eight-month-old babies. Professional Care of Mother & Child. 1996;6(3):68-69.
16 American Academy of Pediatrics. Iron deficiency. Pediatric Nutrition Handbook. Fourth ed. Elk Grove Village, IL: American Academy of Pediatrics; 1998.
17 Wharton BA. Iron deficiency in children: detection and prevention. British Journal of Haematology. 1999;106(2):270-280. [pmid: 10460583].
18 Emond AM, Hawkins N, Pennock C, Golding J. Haemoglobin and ferritin concentrations in infants at 8 months of age. Archives of Disease in Childhood. 1996;74(1):36-39. [pmid: 8660043].
19 Kohli-Kumar M. Screening for Anemia in Children: AAP Recommendations—A Critique. Pediatrics. 2001;108(3):56.
20 Polhamus B, Dalenius K, Thompson D, et al. Pediatric Nutrition Surveillance 2003 Report. Atlanta: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention.; 2004.
21 Bhutta ZA, Darmstadt GL, Hasan BS, Haws RA. Community-Based Interventions for Improving Perinatal and Neonatal Health Outcomes in Developing Countries: A Review of the Evidence. Pediatrics. 2005;115(2):519-617. [pmid: 15866863].
22 Willows ND, Morel J, Gray-Donald K. Prevalence of anemia among James Bay Cree infants of northern Quebec. Can. Med. Assoc. J. 2000;162(3):323-326. [pmid: 10693587].
23 Health in the Americas. Vol 2. Washington, DC: Pan American Health Organization; 1998.
24 Bothwell T, Charlton R. Iron deficiency in women. Washington, DC: The Nutrition Foundation; 1981.
25 Nead KG, Halterman JS, Kaczorowski JM, Auinger P, Weitzman M. Overweight Children and Adolescents: A Risk Group for Iron Deficiency. Pediatrics. 2004;114(1):104-108. [pmid: 15231915].
26 Elwood PC, Waters WE, Greene WJ, Sweetnam P, Wood MM. Symptoms and circulating haemoglobin level. Journal of Chronic Diseases. 1969;21(9):615-628. [pmid: 5770429].
27 Elwood PC. Evaluation of the clinical importance of anemia. American Journal of Clinical Nutrition. 1973;26(9):958-964. [pmid: 4580438].
28 Elwood PC, Waters WE, Benjamin IT, Sweetnam PM. Mortality and anaemia in women. Lancet. 1974;1(7863):891-894. [pmid: 4133418].
29 Lozoff B, Brittenham GM, Wolf AW, et al. Iron deficiency anemia and iron therapy effects on infant developmental test performance. Pediatrics. 1987;79:981-995. [pmid: 2438638].
30 Lozoff B, Jimenez E, Wolf AW. Long-term developmental outcome of infants with iron deficiency. N Engl J Med. 1991;325:687-694. [pmid: 1870641].
31 Oski FA, Honig AS, B H, P H. Effect of iron therapy on behavior performance in nonanemic, iron-deficient infants. Pediatrics. 1983;71:877-880. [pmid: 6856400].
32 Pollitt E. Iron deficiency and cognitive function. Annu Rev Nutr. 1993;13:521-537. [pmid: 8369157].
33 Walter T, de Andraca I, Chadud P, Perales CG. Iron deficiency anemia: adverse effects on infant psychomotor development. Pediatrics. 1989;84:7-17. [pmid: 2472596].
34 Halterman JS, Kaczorowski JM, Aligne CA, Auinger P, Szilagyi PG. Iron Deficiency and Cognitive Achievement Among School-Aged Children and Adolescents in the United States. Pediatrics. 2001;107(6):1381-1386. [pmid: 11389261].
35 Grantham-McGregor S, Ani C. A Review of Studies on the Effect of Iron Deficiency on Cognitive Development in Children. J. Nutr. 2001;131(2):649S-668. [pmid: 11160596].
36 Larkin EC, Rao GA. Brain, behavior, and iron in the infant diet. In: J. D, ed. Brain, Behavior and Iron in the Infant Diet. London: Springer-Verlag; 1990:43–63.
37 Beard J, Erikson KM, Jones BC. Neonatal Iron Deficiency Results in Irreversible Changes in Dopamine Function in Rats. J. Nutr. 2003;133:1174-1179. [pmid: 12672939].
38 Algarin C, Peirano P, Garrido M, Pizarro F, Lozoff B. Iron Deficiency Anemia in Infancy: Long-Lasting Effects on Auditory and Visual System Functioning. Pediatr Res. 2003;53(2):217-223. [pmid: 12538778].
39 Hurtado EK, Claussen AH, Scott KG. Early childhood anemia and mild or moderate mental retardation. Am J Clin Nutr. 1999;69(1):115-119. [pmid: 9925132].
40 Lozoff B, Jimenez E, Hagen J, Mollen E, Wolf AW. Poorer Behavioral and Developmental Outcome More Than 10 Years After Treatment for Iron Deficiency in Infancy. Pediatrics. 2000;105(4):e51. [pmid: 10742372].
41 Black MM. Micronutrient Deficiencies and Cognitive Functioning. J. Nutr. 2003;133:3927S-3931S. [pmid: 14672291].
42 Scanlon KS, Yip R, Schieve LA, Cogswell ME. High and Low Hemoglobin Levels During Pregnancy: Differential Risks for Preterm Birth and Small for Gestational Age. Obstet. Gynecol. 2000;96(5):741-748. [pmid: 11042311].
43 Yip R. Significance of an abnormally low or high hemoglobin concentration during pregnancy: special consideration of iron nutrition. Am J Clin Nutr. 2000;72(suppl):272S-279S. [pmid: 10871593].
44 Rasmussen K. Is there a causal relationship between iron deficiency or iron-deficiency anemia and weight at birth, length of gestation and perinatal mortality?. J Nutr. 2001;131:590S-603S. [pmid: 11160592].
45 Tamura T, Goldenberg RL, Hou J, Johnston KE, Cliver SP, Ramey SL. Cord serum ferritin concentrations and mental and psychomotor development of children at five years of age. J Pediatr. 2002;140(2):165-170. [pmid: 11865266].
46 Corwin EJ, Murray-Kolb LE, Beard JL. Low Hemoglobin Level Is a Risk Factor for Postpartum Depression. J. Nutr. 2003;133(12):4139-4142. [pmid: 14652362].
47 Perez EM, Hendricks MK, Beard JL, et al. Mother-infant interactions and infant development are altered by maternal iron deficiency anemia. Journal of Nutrition. 2005;135(4):850-855. [pmid: 15795446].
48 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third US Preventive Services Task Force. American Journal of Preventive Medicine. 2001;20(3S):21-35. [pmid: 11306229].
49 Bogen DL, Krause JP, Serwint JR. Outcome of children identified as anemic by routine screening in an inner-city clinic. Archives of Pediatrics & Adolescent Medicine. 2003;155(3):366-371. [pmid: 11231803].
50 Logan S. Commentary: Iron deficiency and developmental deficit—the jury is still out. BMJ. 1999;318:697-698. [pmid: 10215375].
51 Logan S. Commentary on iron deficiency anaemia in infancy and early childhood. Arch Dis Child. 1997;76:553-554.
52 Martins S, Logan S, Gilbert R. Iron therapy for improving psychomotor development and cognitive function in children under the age of three with iron deficiency. Cochrane Database of Systematic Reviews. 2001;1.
53 Idjradinata P, Pollitt E. Reversal of developmental delays in iron-deficient anemic infants treated with iron. Lancet. 1993;341:1-4. [pmid: 7678046].
54 Oski FA, Honig AS. The effects of therapy on the developmental score of iron-deficient infants. Journal of Pediatrics. 1978;92(1):21-25. [pmid: 338872].
55 Lozoff B, Brittenham GM, Viteri FE, Wolf AW, Urrutia JJ. The effects of short-term oral iron therapy on development deficits in iron-deficient anemic infants. Journal of Pediatrics. 1982;100(3):351-357. [pmid: 6174719].
56 Aukett MA, Parkes YA, Scott PH, Wharton BA. Treatment with iron increases weight gain in psychomotor development. Arch Dis Child. 1986;61:849-857. [pmid: 2429622].
57 Sachdev H, Gera T, Nestel P. Effect of iron supplementation on mental and motor development in children: systematic review of randomised controlled trials. Public Health Nutrition. 2005;8(2):117-132. [pmid: 15877905].
58 Dienard AS, List A, Lindgren B, Hunt JV, Chang PN. Cognitive deficits in iron-deficient and iron deficient anemic children. Journal of Pediatrics. 1986;108:681-689. [pmid: 3701513].
59 Morley R, Abbotta R, Fairweather-Taitc S, MacFadyend U, Stephensone T, Lucasa A. Iron fortified follow on formula from 9 to 18 months improves iron status but not development or growth: a randomised trial. Arch Dis Child. 1999;81:247-252. [pmid: 10451399].
60 Moffatt MEK, Longstaffe S, Sesant J, Dureski C. Prevention of iron deficiency and psychomotor decline in high risk infant through iron fortified infant formula: a randomized clinical trial. J. Pediatr. 1994;125:527-534. [pmid: 7523647].
61 Driva A, Kafatos A, Salman M. Iron deficiency and the cognitive and psychomotor development of children: a pilot study with institutionalised children. Early Child Development and Care. 1985;22:73-82.
62 Stoltzfus RJ, Kvalsvig JD, Chwaya HM, et al. Effects of iron supplementation and anthelmintic treatment on motor and language development of preschool children in Zanzibar: double blind, placebo controlled study. BMJ. 2001;323(7326):1389-1393. [pmid: 11744561].
63 Lozoff B, De Andraca I, Castillo M, Smith JB, Walter T, Pino P. Behavioral and Developmental Effects of Preventing Iron-Deficiency Anemia in Healthy Full-Term Infants. Pediatrics. 2003;112(4):846-854. [pmid: 14523176].
64 Lind T, Lonnerdal B, Stenlund H, et al. A community-based randomized controlled trial of iron and zinc supplementation in Indonesian infants: effects on growth and development. American Journal of Clinical Nutrition. 2004;80(3):729-736. [pmid: 15321815].
65 Stoltzfus RJ, Chway HM, Montresor A, et al. Low dose daily iron supplementation improves iron status and appetite but not anemia, whereas quarterly anthelminthic treatment improves growth, appetite and anemia in Zanzibari preschool children. Journal of Nutrition. 2004;134(2):348-356. [pmid: 14747671].
66 Williams J, Wolff A, Daly A, et al. Iron supplemented formula milk related to reduction in psychomotor decline in infants from inner city areas: randomised study • Commentary: Iron deficiency and developmental deficit—the jury is still out. BMJ. 1999;318(7185):693-698. [pmid: 10074011].
67 Friel JK, Aziz K, Andrews WL, Harding SV, Courage ML, Adams RJ. A double-masked, randomized control trial of iron supplementation in early infancy in healthy term breast-fed infants. Journal of Pediatrics. 2003;143(5):582-586. [pmid: 14615726].
68 Metallinos-Katsaras E, Valassi-Adam E, Dewey KG, Lonnerdal B, Stamoulakatou A, Pollitt E. Effect of iron supplementation on cognition in Greek preschoolers. European Journal of Clinical Nutrition. 2004;58(11):1532-1542. [pmid: 15226754].
69 Groner JA, Holtzman NA, Charney E, et al. A randomized trial of oral iron on tests of short-term memory and attention span in young pregnant women. J Adolesc Health Care. 1986;7:44-48. [pmid: 3511017].
70 Bruner AB, Joffe A, Duggan AK, Casella JF, J B. Randomized study of cognitive effects of iron supplementation in non-anaemic irondeficient adolescent girls. Lancet. 1996;348:992-996. [pmid: 8855856].
71 Hemminki E, Starfield B. Routine administration of iron and vitamins during pregnancy: review of controlled clinical trials. British Journal of Obstetrics & Gynaecology. 1978;85(6):404-410. [pmid: 350260].
72 Paintin D, Thomson A, Hytten F. Iron and the hemoglobin level in pregnancy. Br J Obstet Gynaecol. 1966;73:181-190.
73 Willoughby ML. An investigation of folic acid requirements in pregnancy. II. British Journal of Haematology. 1967;13(4):503-509. [pmid: 6029952].
74 Primbs K. Iron therapy during pregnancy—a comparitive study. Geburtshilfe und Frauenheilkunde. 1973;33(7):552-559. [pmid: 4581929].
75 Fleming AF, Martin JD, Hahnel R, Westlake AJ. Effects of iron and folic acid antenatal supplements on maternal haematology and fetal wellbeing. Medical Journal of Australia. 1974;2(12):429-436. [pmid: 4431344].
76 Milman N, Bergholt T, Eriksen L, et al. Iron prophylaxis during pregnancy — how much iron is needed? A randomized dose- response study of 20–80 mg ferrous iron daily in pregnant women. Acta Obstetricia et Gynecologica Scandinavica. 2005;84(3):238-247. [pmid: 15715531].
77 Guldholt IS, Trolle BG, Hvidman LE. Iron supplementation during pregnancy. Acta Obstetricia et Gynecologica Scandinavica. 1991;70:9-12. [pmid: 1858501].
78 Mahomed K. Iron supplementation in pregnancy. Cochrane Database of Systematic Reviews. 2005;4:2.
79 Hemminki E, Rimpela U. A randomized comparision of routine versus selective iron supplementation during pregnancy. Journal of the American College of Nutrition. 1991;10(1):3-10. [pmid: 2010577].
80 Hemminki E, Merilainen J. Long term follow-up of mothers and their infants in a randomized trial on iron prophylaxis during pregnancy. Am J Obstet Gynecol. 1995;173(1):205-209. [pmid: 7631683].
81 Cogswell ME, Parvanta, Ickes L, Yip R, Brittenham GM, Ilett S. Iron supplementation during pregnancy, anemia, and birth weight: a randomized controlled trial. Am. J. Clinical Nutrition. 2003;78(4):773-781. [pmid: 14522736].
82 James JA, Laing GJ, Logan S, Rossdale M. Feasibility of screening toddlers for iron deficiency anaemia in general practice. BMJ. 1997;315(7100):102-103. [pmid: 9240051].
83 Schellenberg D, Kahigwa E, Sanz S, et al. A randomized comparison of two anemia treatment regimens in Tanzanian children. American Journal of Tropical Medicine & Hygiene. 2004;71(4):428-433. [pmid: 15516638].
84 Nagpal J, Sachdev HP, Singh T, Mallika V. A randomized placebo-controlled trial of iron supplementation in breastfed young infants initiated on complementary feeding: effect on haematological status. Journal of Health, Population & Nutrition. 2004;22(2):203-211.
85 Ahmed P, Mahmood A, Aziz S, Azim W. Comparison of response between food supplemented with powdered iron and iron in syrup form for iron deficiency anemia. Journal of the College of Physicians & Surgeons Pakistan. 2003;13(7):402-404. [pmid: 12887843].
86 Zlotkin S, Antwi KY, Schauer C, Yeung G. Use of microencapsulated iron(II) fumarate sprinkles to prevent recurrence of anaemia in infants and young children at high risk. Bulletin of the World Health Organization. 2003;81(2):108-115. [pmid: 12756979].
87 Zlotkin S, Arthur P, Schauer C, Antwi KY, Yeung G, Piekarz A. Home-fortification with iron and zinc sprinkles or iron sprinkles alone successfully treats anemia in infants and young children. Journal of Nutrition. 2003;133(4):1075-1080. [pmid: 12672922].
88 Tavil B, Sipahi T, Gokce H, Akar N. Effect of twice weekly versus daily iron treatment in Turkish children with iron deficiency anemia. Pediatric Hematology & Oncology. 2003;20(4):319-326. [pmid: 12746164].
89 Ermis B, Demirel F, Demircan N, Gurel A. Effects of three different iron supplementations in term healthy infants after 5 months of life. Journal of Tropical Pediatrics. 2002;48(5):280-284. [pmid: 12405170].
90 Liyanage C, Zlotkin S. Bioavailability of iron from micro-encapsulated iron sprinkle supplement. Food & Nutrition Bulletin. 2002;23(3 Suppl):133-137. [pmid: 12362781].
91 Nguyen XN, Berger J, Dao TQ, Nguyen CK, Traissac P, Ha HK. Efficacy of daily and weekly iron supplementation for the control of iron deficiency anaemia in infants in rural Vietnam. Sante. 2002;12(1):31-37. [pmid: 11943636].
92 Yurdakok K, Temiz F, Yalcin SS, Gumruk F. Efficacy of daily and weekly iron supplementation on iron status in exclusively breast-fed infants. Journal of Pediatric Hematology/Oncology. 2004;26(5):284-288. [pmid: 15111779].
93 Yang Q, Yin S, Zhao X, An J. Effect of daily or once weekly iron supplementation on growth and iron status of preschool children. Wei Sheng Yen Chiu/Journal of Hygiene Research. 2004;33(2):205-207. [pmid: 15209007].
94 Hall A, Roschnik N, Ouattara F, et al. A randomised trial in Mali of the effectiveness of weekly iron supplements given by teachers on the haemoglobin concentrations of schoolchildren. Public Health Nutrition. 2002;5(3):413-418. [pmid: 12003652].
95 Roschnik N, Parawan A, Baylon MA, Chua T, Hall A. Weekly iron supplements given by teachers sustain the haemoglobin concentration of schoolchildren in the Philippines. Tropical Medicine & International Health. 2004;9(8):904-909. [pmid: 15303996].
96 Agarwal KN, Gomber S, Bisht H, Som M. Anemia prophylaxis in adolescent school girls by weekly or daily iron-folate supplementation. Indian Pediatrics. 2003;40(4):296-301. [pmid: 12736400].
97 Februhartanty J, Dillon D, Khusun H. Will iron supplementation given during menstruation improve iron status better than weekly supplementation?. Asia Pacific Journal of Clinical Nutrition. 2002;11(1):36-41. [pmid: 11890637].
98 Siddiqui IA, Rahman MA, Jaleel A. Efficacy of daily vs. weekly supplementation of iron in schoolchildren with low iron status. Journal of Tropical Pediatrics. 2004;50(5):276-278. [pmid: 15510758].
99 Ash DM, Tatala SR, Frongillo EA Jr, Ndossi GD, Latham MC. Randomized efficacy trial of a micronutrient-fortified beverage in primary school children in Tanzania. American Journal of Clinical Nutrition. 2003;77(4):891-898. [pmid: 12663288].
100 Zimmermann MB, Zeder C, Chaouki N, Saad A, Torresani T, Hurrell RF. Dual fortification of salt with iodine and microencapsulated iron: a randomized, double-blind, controlled trial in Moroccan schoolchildren. American Journal of Clinical Nutrition. 2003;77(2):425-432. [pmid: 12540404].
101 Desai MR, Dhar R, Rosen DH, et al. Daily Iron Supplementation Is More Efficacious than Twice Weekly Iron Supplementation for the Treatment of Childhood Anemia in Western Kenya. J. Nutr. 2004;134(5):1167-1174. [pmid: 15113965].
102 de Souza AI, Batista Filho M, Ferreira LO, Figueiroa JN. The effectiveness of three regimens using ferrous sulfate to treat anemia in pregnant women. Pan American Journal of Public Health. 2004;15(5):313-319. [pmid: 15231078].
103 Sanders W. Drug evaluations: American Medical Association; 1989:591.
104 Reynolds J. Martindale: the extra pharmacopoeia. The Pharmaceutical Press. 1989;29th ed:1189–1190.
105 Litovitz T, Manoguerra A. Comparison of pediatric poisoning hazards: an analysis of 3.8 million exposure incidents. A report from the American Association of Poison Control Centers. Pediatrics. 1992;89:999-1006. [pmid: 1594365].
106 Iron-containing supplements and drugs: label warning statements and unit-dose packaging requirements. Fed Regist. 1997;62:2217–2250.
107 Manoguerra AS, Erdman AR, Booze L, et al. Iron ingestion: an evidence-based consensus guideline for out of hospital management: American Association of Poison Control Centers; May 3, 2005.
108 Iron-containing supplements and drugs; label warning statements and unit-dose packaging requirements; removal of regulations for unit-dose packaging requirements for dietary supplements and drugs. Final rule; removal of regulatory provisions in response to court order. Fed Regist. 2003;68:59714–59715.
109 Gera T, Sachdev HPS. Effect of iron supplementation on incidence of infectious illness in children: systematic review. BMJ. 2002;325(7373):1142-1152. [pmid: 12433763].
110 Section on Breastfeeding. Breastfeeding and the Use of Human Milk. Pediatrics. 2005;115(2):496–506.