# Summary and Discussion

Iron deficiency anemia is a serious problem worldwide. Although it is less common in developed countries such as the United States and Canada, where the use of iron supplemented formula is widespread, within these countries it is still a major concern among vulnerable populations, particularly in recent immigrants, native Americans, and poor African-American communities.

While iron deficiency anemia in infancy is a marker for poor neurocognitive development subsequently, screening and early treatment have not consistently improved these outcomes. Two leading hypotheses have been advanced to explain these disappointing results. One is that prevention of neurodevelopmental consequences of iron deficiency anemia may require acting to prevent iron deficiency in the first place rather than detection and treatment of existing iron deficiency. At present there is little evidence to support this hypothesis, but additional studies, particularly in developing countries, may confirm it. The second hypothesis is that prevention of neurodevelopmental consequences may require screening and early treatment of multiple nutritional deficiencies, rather than iron deficiency anemia alone.

In adolescent girls, a few provocative studies indicate that early detection or prevention of iron deficiency might improve social adjustment and cognitive function. In pregnant women, there are no reliable data from controlled trials about the pregnancy outcomes for either mother or baby. ^78^

Table 7 summarizes the main findings of this update.

Table 7 Summary of the evidence

Question | Group(s) | Findings | Comments
What is the burden of illness of iron deficiency anemia in the U.S.? | All | Overall, prevalence now and in the mid-1990s is similar. Prevalence in the groups targeted for screening are: Infants 1– 2 years (7%), teenage girls (9%), non-pregnant females of reproductive age (12%). | -
Prevalence | All | Estimated prevalence in the groups targeted for screening are: Infants 1–2 years (6 to 17 per 1000), teenage girls (1.5%), non-pregnant females of reproductive age (2% to 5%). The prevalence among pregnant women is uncertain. | -
Risk Factors | All | Risk factors include female sex, black or Mexican-American race, Alaskan native heritage, recent immigration, poverty, and among teenage girls, fad dieting or obesity. Premature and low birth weight infants are at high risk. | -
Complications | Infants and children | In cross-sectional and longitudinal cohort studies, iron deficiency anemia as an infant is associated with long-term psychomotor and cognitive abnormalities, poor school performance, and mental retardation. However, confounding due to environmental, socioeconomic, and other nutritional factors cannot be excluded. | -
| Pregnant women | Low or high hemoglobin values in the first trimester are associated with an increased risk of premature birth. Maternal anemia may be associated with poorer parental interaction and poorer developmental outcomes at 9 months of age. | -
| All | Severe iron deficiency anemia is symptomatic (fatigue, reduced endurance) and reduces work productivity. | -
Is there direct evidence that screening for iron deficiency anemia results in improved health outcomes? | Infants and children | (Poor.) In controlled trials and time-series studies, screening and treatment for iron deficiency anemia can reduce the prevalence of iron deficiency anemia in high-risk populations, but there are no data that directly link screening with better neurodevelopmental outcomes. | -
Does early iron supplementation in people with (or at risk for) iron deficiency anemia improve neurodevelopmental outcomes? | Infants and children | (Fair.) The results of trials are mixed. Most trials conducted in high-risk groups within developed countries did not demonstrate any benefit for infants and preschool children, but in one trial in high-risk infants there was a transient benefit. | -
| Older children | (Fair.) Iron supplementation for infants aged 3–6 months improves growth and weight gain in anemic, malnourished children aged 7–10 years in developing countries. There is no evidence directly relevant to screening in the U.S. | -
| Adolescent girls | (Poor.) In girls who had iron deficiency but not iron deficiency anemia, iron supplementation improved performance on tests of verbal learning, but the magnitude or duration of the benefit was not clear. | -
| Pregnant girls and women (effect on the mother) | (Poor.) In one small trial conducted in Baltimore in the early 1980s, supplementation improved short-term memory and attention span. In a South African trial, treatment of anemic mothers enrolled at 6–8 weeks postpartum improved parenting (Parent/Caregiver Involvement Scale) assessed at 9 months. | -
| Pregnant girls and women (effect on the child) | (Fair.) Most studies of treatment found no effect on birth outcome. The most recent trial found a substantial increase in birth weight, but had important flaws. | -
What are the adverse effects of screening for iron deficiency anemia? | Infants and children | No evidence. | Potential harms: cost, time, anxiety, false-positives
What are the adverse effects of iron supplementation? | Infants and children | (Good.) Accidental overdose is the most serious potential adverse event. Diarrhea is a common side effect (incidence rate difference 0.05 episodes/child year, -0.03 to 0.13; P=0.21). Cohort studies have reported no important adverse effects with iron-fortified formula, nor were serious side effects reported in the clinical trials of iron-fortified food or formula. | No new evidence of additional harms. There is good evidence that overdose of iron can cause fatal poisoning.
| Pregnant women | (Poor.) In one Finnish trial of pregnant women, routine iron supplementation led to a higher cesarean section rate, but this result has not been verified. | -