# Recommendations of Other Groups

In 1998, the Centers for Disease Control and Prevention (CDC) published recommendations to prevent and control iron deficiency. ^5^ In addition to pregnant women and high-risk infants, the CDC recommended screening among high-risk preschool children and among nonpregnant women of childbearing age. The CDC also recommended “universal iron supplementation to meet the iron requirements of pregnancy.”

The American Academy of Pediatricians (AAP) recommends checking hemoglobin (or hematocrit) between 9 and 12 months of age and then 6 months later, and, for patients at high risk, once a year from age 2 to 5 years. Screening may be universal or selective depending on the prevalence of IDA in the local or demographic population. The AAP also recommends that adolescent girls be screened for anemia during all routine physical examinations. ^16^

The 2005 AAP breastfeeding guidelines recommend continuing breastfeeding for at least the first year of life and beyond, while introducing complementary foods rich in iron beginning around 6 months of age. Preterm and low birth weight infants and infants with hematologic disorders, or infants who had inadequate iron stores at birth, generally require iron supplementation before 6 months of age. The AAP recommends that infants weaned before 12 months of age receive iron-fortified infant formula instead of cow's milk. ^110^

The American Academy of Family Physicians (AAFP) recommends screening for IDA by obtaining hemoglobin and/or hematocrit levels in infants aged 6 to 12 months who are living in poverty, or who are black, Native American, or Alaska Native, immigrants from developing countries, preterm and low birth weight infants, and infants whose principal dietary intake is unfortified cow's milk.

The American College of Obstetricians and Gynecologists (ACOG) recommends prenatal screening for all women at the earliest prenatal visit and early in the third trimester. Screening of older children or nonpregnant adolescents and adults is not recommended.

The Veterans Administration/Department of Defense guideline panel found insufficient evidence to recommend for or against routinely supplementing iron for all pregnant women who are not anemic. They recommended supplementation with at least 50 mg elemental iron (325 mg ferrous sulfate) twice a day in all pregnant women diagnosed with anemia (hematocrit <30).