# Results

Is there direct evidence that screening for iron deficiency anemia in asymptomatic children aged 6–12 months results in improved health outcomes; that is, abnormal infant behavior, growth, development (longer-term outcomes)?

We did not find any controlled trials of screening for IDA. In the United States, an uncontrolled, practice-based study conducted at the pediatric resident clinic at Johns Hopkins University described the results of an effort to implement the screening strategy recommended by the American Academy of Pediatrics. ^49^ Of 1358 clinic patients aged 9–36 months who were screened, 343 (25%) had an Hgb level less than 110 g/L. About half of these infants had mild anemia (Hgb 106 to 109 g/L). Of these, 75 were prescribed iron and anemia resolved by 6 months of follow-up in 55 (73%). Another 25 were not prescribed iron, and anemia resolved by 6 months in 21 (84%). For those who had Hgb levels <106 g/L, 61 of 90 (68%) treated children resolved by 6 months, versus 6 of 15 (40%) untreated children.

Is there evidence that early iron supplementation in infants, children, adolescent girls, or pregnant women with iron deficiency anemia improves outcomes?

Infants and children. Improved growth and weight gain with 3–6 months of iron supplementation have been reported consistently in placebo-controlled trials of anemic, malnourished children in developing countries.

Whether treatment is also associated with improvements in cognition, behavior, and motor development is less clear. The U.S. Preventive Services Task Force, in 1996, noted that trials of treatment of infants with IDA to improve neurodevelopmental outcomes had conflicting results. Some of the trials reporting a benefit had serious flaws. ^50,^ ^51^ A Cochrane review, published in 2001, found seven trials of treatment in children up to 3 years of age; all these trials were published prior to 1994 and had been cited in the Task Force's review (Table 4). ^52^ The Cochrane review concluded that there was a lack of clear evidence of a beneficial effect on psychomotor development.

Table 4 Neurodevelopmental outcomes in children under age 3 with iron deficiency anemia (articles included in Cochrane Review and 1996 USPSTF reviews)

Trial (Funding Source) | Setting | Subjects | Age (mos.) | N | Design Characteristics | Treatment (duration) | Control | Follow-up Assessment | Time | Results
Oski and Honig, 1978 ^54^ | Pediatric Clinic in New York | IDA (Hgb<10.5 g/dl) | 9–29 | 24 | DBRCT. No details of allocation process available. | IM iron dextran complex once. | Placebo of IM sterile saline once. | BSID, BIB. | 1 wk. | Improved alertness, gross and fine motor coordination.
Lozoff, 1982 ^55^ | Community volunteers, Guatemala | IDA (Hgb<10.5 g/dl) | 6–24 | 28 | DBRCT. Allocation by investigators not connected with study. | Oral iron for 7 days. | Placebo. | BSID. | 6 –8 days | NS trend in PDI, no difference in MDI.
Lozoff, 1987 ^29^ | - | Anemia (Hgb<=10.5g/dl) | - | 52 | DBRCT. Allocation by investigators not connected with study. | IM or oral iron for 7 days. | Placebo. | BSID. | 7 days | No difference.
Walter, 1989 ^33^ | Community sample, Chile | IDA (Hgb<10.5g/dl) | 12 | 39 | Unclear. Method of allocation unclear. | Ferrous sulphate 45 mg day for 10 days. | Placebo. | BSID. | 3 mos. | No difference.
Kimmons, unpublished | General pediatric clinic, U.K. | IDA (Hgb<10.6g/dl, MCV<73) | 6 –24 | 42 | DBRCT. Allocation by nurse not connected with study. | IM Iron dextran complex. | Placebo. | BSID. | 1 wk. | No difference.
Aukett, 1986 ^56^ | Community Sample | IDA (Hgb 8–11g/dl) | 17–19 | 110 | DBRCT. Allocation by investigators not connected with study. | Oral iron plus vitamin C. | Placebo. | DDST, weight change. | 8–9 wks. | No difference.
Idjradinata, 1993 ^53^ | Pediatric clinic in Indonesia | IDA (Hgb<=10.5g/dl) | 12–18 | 50 | DBRCT. | Oral iron for 4 months. | Placebo. | BSID, weight, length. | 4 mos. | PDI + 18.4
| | | | | | | | | | MDI + 18.8

BSID = Bayley Scales of Infant Development, DBRCT= Double-blinded randomized controlled trial, DDST = Denver Development Screening Test, Hgb = Hemoglobin, IDA = Iron deficiency anemia, IM= Intramuscular, MCV = Mean corpuscular volume, MDI = Mental Development Index, NS = Not significant, PDI = Psychomotor Development Index, USPSTF = U.S. Preventive Services Task Force

A review by Grantham-McGregor and colleagues included trials as well as observational studies. ^35^ With the exception of one trial published in 1993, ^53^ short-term and longer-term trials found no benefit of iron supplementation on intelligence tests, tests of cognitive function, or other neurodevelopmental outcomes, and the observational studies had not adequately addressed potential confounders.

The conflicting results in trials of treatment for IDA have called into question the reversibility of neurodevelopmental abnormalities associated with IDA, and have led to increased interest in preventing rather than remediating iron deficiency. Until recently, few trials of primary prevention examined neurocognitive or behavioral endpoints. Moreover, as many studies do not distinguish between high-risk subjects who have IDA and those who have iron deficiency without anemia, it is very difficult to distinguish the effect of prophylactic iron supplementation from the effect of treatment of existing iron deficiency.

A recent meta-analysis ^57^ combined 17 trials of iron supplementation in infants or in children up to 12 years of age. Sixteen trials were published 2001 or earlier and one was unpublished. Ten of the trials were conducted in developing countries, two were from the United States, ^31,^ ^58^ two were from the United Kingdom, ^56,^ ^59^ one was from Canada, ^60^ and one was from Greece. ^61^ The main measure was the “mental development score,” derived by combining any available scores from the Bayley Mental Development Index (MDI), Stanford Binet Test, Peabody Picture Vocabulary Test (PPVT), IQ, and cognition tests. Overall, the standard mean difference in mental development scores was 0.30 (95% CI, 0.15 to 0.46, p< 0.001), a difference equivalent to equivalent to 1.5 to 2 points on a scale of 100. Separate analyses for mental development tests and motor development found no statistically significant differences.

The trials pooled in this meta-analysis included diverse subjects, settings, clinical interventions, and outcome measures. Because of this heterogeneity, the overall pooled result has little or no applicability to the United States. In subgroup analyses, the improvement in mental development scores was attributable to five trials in children aged 7 years and older (standard mean difference, 0.44; 94% CI, 0.21–0.66, p<0.0001) conducted in India (2), Thailand (1), and Indonesia (2). The effect was small and statistically not significant for infants under 2 years of age (0.15, CI 0.04–0.34, p=0.128). The effect is intermediate for children between 2 and 5 years of age. ^62^ More recent trials in developing countries have had mixed results (Table 5 and Evidence Table 1, Panel 1). ^63^ – ^65^

Table 5 Recent trials of iron supplementation on cognitive or motor development in developing countries

Trial /Design | Subjects /Setting | Results
Lozoff, 2003 ^63^ | 1657 infants 6 or fewer months old | Bayley Scales and Fagan test of Infant Intelligence at 12 months. No difference in PDI or MDI scores at 12 months.
Partly randomized | Chile | On Fagan test, mean looking time was longer in the no-iron-added group (1.39 ± 0.02 seconds vs. 1.46 ± 0.04).
Lind, 2004 ^64^ | 680 full-term infants aged 6 months | Bayley Scores at 12 months.
RCT | Indonesia | PDI in Iron group 106 ± 11 vs. placebo group 103 ± 10.8.
| | MDI in Iron group 101 ± 9.3 vs. placebo group 99 ± 10.
| | No difference in Behavioral Rating Scale.

MDI = Mental Development Index, PDI = Psychomotor Development Index, RCT = Randomized controlled trial

In their review, Grantham-McGregor ^35^ and colleagues identified three prevention trials conducted in developed countries ^59,^ ^60,^ ^66^ that measured motor, cognitive, or behavioral function. One ^60^ of these, conducted in Canada, was reviewed by the USPSTF previously. In this trial, infants from very low-income families were randomized to take iron-fortified versus unfortified formula. Those who were fed iron-fortified formula had significantly higher Bayley motor scores at 9 and 12 months. By 18 months there was no longer any effect, but by that time 46% of the subjects had been lost to follow-up.

Trials conducted in developed countries and published since the last USPSTF review are summarized in Table 6 (see Evidence Table 1, Panel 2 for more details). Two trials (which were included in the review by Grantham-McGregor and colleagues) evaluated iron-fortified formula in low socioeconomic status areas of the United Kingdom. ^59,^ ^66^ We also identified a Canadian trial of iron supplementation in infants 1 to 6 months of age ^67^ and one of preschoolers conducted in nine day care centers in Athens, Greece,68 neither of which has been included in previous systematic reviews.

Table 6 Effect of iron supplementation on infants in developed countries

Trial / Design | Subjects / Setting | Results
Developed countries
Williams, 1999 ^66^ | 100 full-term infants aged 6–8 months | Griffith's scale at 18 and 24 months. No differences at 18 months. At 24 months, global developmental quotient fell 5.4 points more in the non-fortified group than in the fortified group (P<0.05).
RCT | Low-income England
Morley, 1999 ^59^ | 493 full-term infants aged 9 months. | MDI and PDI at 18 months. No differences.
RCT | England
Friel, 2003 ^67^ | 77 full-term infants aged 1 month | MDI, PDI and vision at 13 months. PDI scores were higher in the iron supplemented group (100 ± 12 vs. 93 ± 9; normal range 85 to 115). MDI scores did not differ. A trend (P = .07) was observed toward improved visual acuity with iron.
RCT | Canada
Metallinos-Katsaras, 2004 ^68^ | 49 3- 4-year olds (21 anemic, 28 good iron status) | Small improvement in discrimination, specifically selective attention in anemic children, but not others.
RCT | Greece

MDI = Mental Development Index, PDI = Psychomotor Development Index, RCT = Randomized controlled trial

Adolescent girls. An older trial (1986) of pregnant young women found better performance on psychometric tests in women treated with iron than in controls. ^69^ A more recent placebo-controlled trial (published in 1996), conducted in two public and two private Catholic high schools in Baltimore, Maryland in 1993, examined the effects of iron supplementation on cognitive function in nonanemic, iron-deficient adolescent girls. ^70^ Of 716 girls in grades 9–12 (aged 13–18) screened, 35 were found to have anemia (Hgb<11·5 g/dL for African American girls or <12·0 g/dL for white girls) and 98 had iron deficiency without anemia. Eighty-one of these 98 girls agreed to participate in a randomized trial and 73 of them completed the 8-week follow-up period. Girls randomized to treatment took two 325 mg tablets of nonprescription ferrous sulfate twice daily (260 mg elemental iron daily.) Four cognitive tests were administered at baseline and after 8 weeks of treatment. Although more girls in the treatment group than in the placebo group noticed changes in stool color (65% v 10%, p<0.001), the percentage of girls who correctly guessed their group assignment did not differ significantly between groups (62% in treatment compared with 45% of controls, p=0.18).

The four tests were the Symbol Digit Modalities Test (SDMT); Visual Search and Attention Test (VSAT); Brief Test of Attention (BTA); and the Hopkins Verbal Learning Test (HVLT). Only subjects who completed the study were included in the analysis. Treatment had no effect on the SDMT, VSAT, or BTA, all of which are considered to be tests of attention. The authors described the other test, HVLT, as follows:

“The HVLT is a 12-item, semantically categorized word-list learning test with three free recall trials, a delayed recall trial, and yes/no recognition; participants are read the same list of words three times and each time are asked to repeat as many words as they can recall; 20 minutes later they are asked to say which words they remember, and are read 24 words which include the original 12 words plus 12 semantically related and unrelated words.” ^70^

By the author's description, the HVLT, which is considered a test of learning, is scored in three parts—the sum of the three recall trials (the “total recall score”), the delayed recall trial, and the recognition part. The article reported an average baseline HVLT total recall score for the treatment and placebo groups, but did not report the post-treatment scores. The authors state that “on the total recall score of the HVLT (sum of trials 1–3), girls who took iron showed significant improvement over baseline and end of treatment compared with the control group (p<0·02). Baseline performance on the HVLT accounted for 93% of the variability in post-intervention scores, whereas treatment condition accounted for the remainder. However, there were no significant differences between groups in other components of the HVLT (delayed recall, yes/no recognition).” From the published results, it is impossible to determine the magnitude of effect or how many girls' scores improved, stayed the same, or worsened in each group.

Pregnant women. A large body of data suggests that iron supplements are effective in improving the hematologic indices of pregnant women, but there is limited evidence that improving hematologic indices in anemic women results in improved clinical outcomes for the mother, fetus, or newborn. Clinical trials have reported that iron supplements in healthy pregnant women with initial hemoglobins ≥ 10 g/dL are efficacious in correcting red cell indices and iron stores, but they do not improve birth weight, length of gestation, or other outcome measures when compared with placebo or with no supplements. ^71^ – ^77^ A 2005 review of community-based interventions to improve perinatal and maternal outcomes in developing countries also found no clear evidence that iron supplementation improved maternal and perinatal or neonatal outcomes. ^21^

A Cochrane review found that iron supplementation appears to prevent low hemoglobin at birth or at 6 weeks postpartum, but concluded there were no reliable data from controlled trials about the pregnancy outcomes for either mother or baby. ^78^ The largest trial included in the Cochrane review compared selective versus routine supplementation in 2693 pregnant Finnish women. ^79^ The initial results of this trial showed a statistically significant increased likelihood of cesarean section (OR 1.36; 95% CI, 1.04 –1.78) and of post-partum blood transfusion (OR 1.68; 95% CI, 1.05 –2.67) in the selective supplementation group compared with routine supplementation. The authors attributed the increased cesarean sections and blood transfusion rates to possible anxiety by midwives and obstetricians about low hematocrit values in the selectively supplemented group. Selective supplementation was associated with a significantly reduced risk of stillbirth after 28 weeks' gestation and of death in the first 7 days after birth. There were also fewer women in this group who complained of side effects from the medication. In a 7-year follow-up study, fewer infants in the selective supplementation group had been hospitalized for convulsions (OR 0.44; 95% CI, 0.25–0.79). ^80^

The Cochrane review did not include an American trial published in 2003 of iron supplementation in 275 low-income pregnant women who had a hemoglobin concentration >110 g/L and a ferritin concentration >20 g/L. ^81^ The women were enrolled before 20 weeks of gestation and randomly assigned to receive a monthly supply of capsules containing either 30 mg iron as ferrous sulfate or placebo until 28 weeks of gestation. For unclear reasons, women assigned to the placebo group had higher baseline pre-pregnancy weight (77.9kg ± 24.3 vs. 72.5kg ± 20.3, p=0.04) and initial ferritin levels (49.4μg/L vs. 44.7μg/L, p=0.0168). Of these 275 women, 62 were excluded from the analysis because the investigators could not obtain birth weights. For the 213 newborns included in the analysis, birth weight < 2,500 grams occurred less frequently in the iron supplementation group (4.3% vs. 16.7%, p=0.003), though the risk of preterm delivery was not different (12.8% vs. 12.5%.)

What are the adverse effects of screening for iron deficiency anemia?

We did not identify any studies of the harms of screening for IDA.

What are the adverse effects of iron supplementation?

Many infants dislike the taste of oral iron preparations or have gastrointestinal side effects. The likelihood of response to treatment for iron deficiency anemia identified by screening is unclear because so many families or infants do not accept treatment and because the rate of spontaneous resolution is high. In the population-based Millennium Baby Study cohort from Glasgow, UK, for example, 147 children aged 13 months were offered treatment because they had a low Hgb, ferritin, MCV, MCH, or high protoporphyrin level. ^7^ Of these, 124 families accepted the first bottle of oral iron, but only 83 accepted a second bottle 3 weeks later. Thirty-one families reported that iron had caused diarrhea and many infants refused to go back on iron-fortified formula milk. A practice-based UK general practitioner study noted similar problems. ^82^

Many controlled trials of iron have examined whether new forms of iron replacement, combinations of micronutrients, and iron regimens requiring less frequent dosing can improve compliance and iron status in infants, ^83^ – ^92^ preschool children, ^93,^ ^94^ school children (including adolescents), ^95^ – ^100^ and pregnant women. ^101,^ ^102^

Adverse effects of iron therapy include unpleasant gastrointestinal symptoms (e.g., nausea and constipation) that are dose-related and, at normal doses, reversible. Iron therapy can cause complications of excessive iron storage in patients with an underlying iron storage disorder (e.g., idiopathic hemochromatosis). ^103,^ ^104^ A potential hazard of iron supplements is unintentional overdose by children in the home. Iron overdose is a concern because it has been observed even in the context of controlled trials and screening programs in which parents were instructed in the safe storage and use of iron-containing products.

Iron supplements accounted for 30% of fatal pediatric pharmaceutical overdoses occurring between 1983 and 1990. ^105^ In 1997, to reduce the danger of overdosage, the U.S. Food and Drug Administration (FDA) required unit-dose packaging for iron-containing dietary supplement and drug products that contain 30 milligrams (mg) or more of iron per dosage unit. ^106^ According to an analysis of American Association of Poison Control Center Toxic Substance Surveillance System (AAPCCTSSS) abstracts, the regulations were associated with a reduction in deaths of children from iron ingestions. From 1983 through 2000, a review of the AAPCCTSSS system showed that at least 43 children had died from the ingestion of iron supplements, but only one child was reported to have died from the ingestion of an iron-containing product from 1998 through 2002 while the regulation was in effect. ^107^

In October 2003, the FDA withdrew this requirement in response to a court ruling in the case of Nutritional Health Alliance versus FDA, in which the Court concluded that the Federal Food, Drug, and Cosmetic Act does not provide the FDA with authority to require manufacturers of iron-containing dietary supplement and drug products to use unit-dose packaging for poison prevention purposes. ^108^ All iron-containing supplements must carry the warning “Accidental overdose of iron-containing products is a leading cause of fatal poisoning in children under 6.”

Other potential adverse effects of iron mentioned in the literature (e.g., birth defects, cancer, heart disease, metabolic imbalances of other minerals, and harmfully high hemoglobin levels) have not been proven. A recent meta-analysis of 28 placebo-controlled trials of iron supplements in 7,892 infants and children found no increased risk of infection (1.02 [95% CI, 0.96–1.08]) and an 11% increase in the risk of diarrhea corresponding to one episode per 20 children per year (95% CI, 1.01–1.23; P=0.04). ^109^