# Methods

## Problem Formulation

Members of the USPSTF defined the scope of this update with input from Agency for Healthcare Research and Quality (AHRQ) and Evidence-based Practice Center (EPC) personnel.

### Search for New Studies

The search was focused on the following key questions:

- Is there direct evidence that screening for iron deficiency in asymptomatic children aged 6–12 months results in improved health outcomes; that is, abnormal infant behavior, growth, and development (longer-term outcomes)?
- Is there evidence that early iron supplementation in infants, children, adolescent girls, or pregnant women with iron deficiency anemia improves these outcomes?
- What are the adverse effects of screening for iron deficiency anemia?
- What are the adverse effects of iron supplementation?

EPC personnel searched the Cochrane Database of Systematic Reviews (2005, v.2), Cochrane CENTRAL (2005, v.2), reference lists of review articles, and tables of contents of leading pediatric journals for studies published 1995 or later that contained new information about the prevalence, diagnosis, natural course, or treatment of iron deficiency anemia in asymptomatic persons. We also searched the web site of the I ron D eficiency P roject A dvisory S ervice Working Group on Iron Deficiency Anemia in Children < 2 (http://www.micronutrient.org/idpas/WorkingGroup.html), which maintains bibliographies and reprints of articles about the prevalence and cognitive consequences of iron deficiency in developing countries.

Articles that met the following criteria were included in this update:

1) The study was a systematic review, prospective cohort study, controlled trial, quasi-experimental study with concurrent controls, or case-control study; not a case series, case report, or comparison with historical controls.
2) The study was not included in the 1996 review.
3) The study was rated at least “fair-quality” using the USPSTF criteria for internal validity. ^48^

### Synthesis

Eligible studies were rated and abstracted by one investigator. Because several recent meta-analyses were available, the investigator did not conduct a new quantitative synthesis; instead the focus was on reporting the results of a critical appraisal of trials published since the USPSTF's 1996 guideline. USPSTF members also reviewed key studies identified in the review.