# Introduction

Iron deficiency anemia has been associated with psychomotor and cognitive abnormalities and poor school performance in children, and with poor pregnancy outcome in pregnant women. In 1996, the U.S. Preventive Task Force (USPSTF) recommended one-time screening for iron deficiency anemia using hemoglobin or hematocrit for pregnant women and for high-risk infants, but not for other groups. ^1^ The Task Force recommended against routine testing for anemia in other children and in adults because of low prevalence, cost, and potential adverse effects of iron therapy. ^2^

We undertook a limited review of recent literature to assist the USPSTF in updating its recommendations. This review was focused on key questions addressing gaps in the evidence that were identified in the USPSTF's 1996 review of screening for and treating iron deficiency anemia. Specifically, the critical key questions were:

- Is there direct evidence that screening for iron deficiency in asymptomatic children results in improved behavioral, motor, or cognitive development and/or growth?
- Does early iron supplementation in infants, children, adolescent girls, or pregnant women with iron deficiency anemia improve these outcomes?
- What are the adverse effects of screening for iron deficiency anemia?
- What are the adverse effects of iron supplementation?

For this review, we focused on studies conducted in developed countries that addressed one or more of these questions.