# References

1 Anderson KM, Castelli WP, Levy D Cholesterol and mortality: 30 years of follow-up from the Framingham study JAMA. 19872572176 2180 3560398
2 Neaton JD, Wentworth D Serum cholesterol, blood pressure, cigarette smoking, and death from coronary heart disease: Overall findings and differences by age for 316,099 white men: Multiple Risk Factor Intervention Trial Research Group Arch Intern Med. 199215256 64
3 National Cholesterol Education Program
4 Gross CP, Anderson GF, Powe NR The relation between funding by the National Institutes of Health and the burden of disease N Engl J Med. 19993401881 1887
5 Centers for Disease Control and Prevention http://www.cdc.gov/nchs/about/major/datatblelink.htm
6 Centers for Disease Control and Prevention http://www.cdc.gov/nchs/about/major/nhanes/datalink.htm
7 Lloyd-Jones DM, Larson MG, Beiser A, Levy D Lifetime risk of developing coronary heart disease Lancet. 199935389 92
8 Sempos CT, Cleeman JI, Carroll MD, et al Prevalence of High Blood Cholesterol Among US Adults JAMA. 19932693009 3014
9 Third National Health and Nutrition Examination Survey, 1988-1994 [database on CD-ROM]. , Hyattsville, MD.
10 Wilson PW, D'Agostino RB, Levy D, Belanger AM, Silbershatz H, Kannel WB Prediction of coronary heart disease using risk factor categories Circulation. 1998971837 1847
11 Grundy SM, Cleeman JI, Rifkind BM, Kuller LH Cholesterol lowering in the elderly population: Coordinating Committee of the National Cholesterol Education Program Arch Intern Med. 19991591670 1678
12 US Preventive Services Task Force Guide to Clinical Preventive Services , Alexandria, Va.
13 The Scandinavian Simvastatin Survival Study (4S). Randomised trial of cholesterol lowering in 4444 patients with coronary heart disease Lancet. 1994344(8934)1383 1389
14 Miettinen TA, Pyorala K, Olsson AG, et al Cholesterol-lowering therapy in women and elderly patients with myocardial infarction or angina pectoris: findings from the Scandinavian Simvastatin Survival Study (4S) Circulation. 1997964211 4218
15 The Long-Term Intervention with Pravastatin in Ischaemic Disease (LIPID) Study Group. Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels N Engl J Med. 19983391349 1357
16 Sacks FM, Pfeffer MA, Moye LA, et al The effect of pravastatin on coronary events after myocardial infarction in patients with average cholesterol levels: Cholesterol and Recurrent Events Trial investigators N Engl J Med. 1996335(14)1001 1009
17 Lewis SJ, Moye LA, Sacks FM, et al Effect of pravastatin on cardiovascular events in older patients with myocardial infarction and cholesterol levels in the average range: Results of the Cholesterol and Recurrent Events (CARE) trial Ann Intern Med. 1998129(9)681 689
18 Rubins HB, Robins SJ, Collins D, et al Gemfibrozil for the secondary prevention of coronary heart disease in men with low levels of high-density lipoprotein cholesterol N Engl J Med. 1999341410 418
19 Majumdar SR, Gurwitz JH, Soumerai SB Undertreatment of hyperlipidemia in the secondary prevention of coronary artery disease J Gen Intern Med. 199914711 717
20 American College of Physicians Guidelines for using serum cholesterol, high-density lipoprotein cholesterol, and triglyceride levels as screening tests for preventing coronary heart disease in adults Ann Intern Med. 1996124515 517
21 Garber AM, Browner WS, Hulley SB Cholesterol screening in asymptomatic adults, revisited, Part 2 Ann Intern Med. 1996124(5)518 531
22 Logan AG. Lowering the blood total cholesterol level to prevent coronary heart disease: Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventive Health Care. 1994:650-669.
23 American Diabetes Association. Clinical practice recommendations 1999. Diabetes Care.
24 American Academy of Pediatrics National Cholesterol Education Program: Report of the Expert Panel on Blood Cholesterol Levels in Children and Adolescents Pediatrics. 199289525 584
25 American Academy of Pediatrics Committee on Nutrition Cholesterol in Childhood (RE9805) Pediatrics. 1998101141 147 11345978
26 Pignone MP, Phillips CJ, Atkins D, Teutsch SM, Mulrow CD, Lohr KN Am J Prev Med. 200120(3S)
27 Harris RP, Helfand M, Woolf SH, et al Am J Prev Med. 200120(3S)
28 Anonymous Cochrane Controlled Trials Registryhttp://cochrane.hcn.net.au/CLIB/CLIBINET.EXE?S=0&Q;=951241599&U;=&A;=2&B;=0&E;=0&R;=0&F;=&H;=&D;=8&L;=1&N;=25&M;=268824&C;=0&T;=*
29 Dorr AE, Gundersen K, Schneider JCJ, Spencer TW, Martin WB Colestipol hydrochloride in hypercholesterolemic patients--effect on serum cholesterol and mortality J Chronic Dis . 1978315 14
30 McCaughan D The long-term effects of probucol on serum lipid levels Arch Intern Med. 19811411428 1432
31 Bradford RH, Shear CL, Chremos AN, et al Expanded Clinical Evaluation of Lovastatin (EXCEL) study results, I: Efficacy in modifying plasma lipoproteins and adverse event profile in 8245 patients with moderate hypercholesterolemia Arch Intern Med. 199115143 49
32 Bradford RH, Shear CL, Chremos AN, et al Expanded Clinical Evaluation of Lovastatin (EXCEL) study results: two-year efficacy and safety follow-up Am J Cardiol. 199474(7)667 673
33 The Pravastatin Multinational Study Group for Cardiac Risk Patients. Am J Cardiol. 1993721031 1037
34 Athyros VG, Papageorgiou AA, Hatzikonstandinou HA, et al Safety and efficacy of long-term statin-fibrate combinations in patients with refractory familial combined hyperlipidemia Am J Cardiol. 199780(5)608 613
35 Ives DG, Kuller LH, Traven ND Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects Am J Prev Med. 19939274 281
36 Lansberg PJ, Mitchel YB, Shapiro D, et al Long-term efficacy and tolerability of simvastatin in a large cohort of elderly hypercholesterolemic patients Atheroscl. 1995116(2)153 162
37 Bredie SJ, Westerveld HT, Knipscheer HC, de Bruin T, Kastelein JJ, Stalenhoef AF Effects of gemfibrozil or simvastatin on apolipoprotein-B-containing lipoproteins, apolipoprotein-CIII and lipoprotein(a) in familial combined hyperlipidaemia Neth J Med. 199649(2)59 67
38 Eriksson M, Hadell K, Holme I, Walldius G, Kjellstrom T Compliance with and efficacy of treatment with pravastatin and cholestyramine: a randomized study on lipid-lowering in primary care J Intern Med. 1998243(5)373 380
39 The Kyushu Lipid Intervention Study Group. A coronary primary intervention study of Japanese men; study design, implementation and baseline data J Atheroscl Thromb. 19963(2)95 104
40 Itoh T, Matsumoto M, Hougaku H, et al Effects of low-dose simvastatin therapy on serum lipid levels in patients with moderate hypercholesterolemia, a 12-month study: The Simvastatin Study Group Clin Ther. 199719(3)487 497
41 Committee of Principal Investigators. A co-operative trial in the primary prevention of ischaemic heart disease using clofibrate: Report from the Committee of Principal Investigators Brit Heart J. 197840(10)1069 1118
42 Luepker RV, Smith LK, Rothchild SS, Gillis A, Kochman L, Warbasse JR Management of hypercholesterolemia: evaluation of practical clinical approaches in healthy young adults Am J Cardiol. 197841(3)590 596
43 van Beurden E, James R, Dunn T, Tyler C Risk assessment and dietary counselling for cholesterol reduction Health Education and Research: Theory and Practice. 19905445 450
44 Jones RJ, Turner D, Ginther J, Brandt B, Slowie L, Lauger G A randomized study of instructional variations in nutrition counseling and their efficacy in the treatment of hyperlipidemia Am J Clin Nutr. 197932(4)884 904
45 Cunningham DA, Rechnitzer PA, Howard JH, Donner AP Exercise training of men at retirement: a clinical trial J Gerontol. 19874217 23
46 Gemson DH, Sloan RP, Messeri P, Goldberg IJ A public health model for cardiovascular risk reduction: impact of cholesterol screening with brief nonphysician counseling Arch Intern Med. 1990150(5)985 989
47 Kuehl KS, Cockerham JT, Hitchings M, Slater D, Nixon G, Rifai N Effective control of hypercholesterolemia in children with dietary interventions based in pediatric practice Prev Med. 199322154 166
48 Heller RF, Walker RJ, Boyle CA, O'Connell DL, Rusakaniko S, Dobson AJ A randomised controlled trial of a dietary advice program for relatives of heart attack victims Med J Aust. 1994161(9)529 531
49 Rivellese AA, Auletta P, Marotta G, et al Long term metabolic effects of two dietary methods of treating hyperlipidaemia BMJ. 1994308227 231
50 Johnston HJ, Jones M, Ridler-Dutton G, Spechler F, Stokes GS, Wyndham LE Diet modification in lowering plasma cholesterol levels: A randomised trial of three types of intervention Med J Austral. 1995162(10)524 526
51 Walden CE, Retzlaff BM, Buck BL, McCann BS, Knopp RH Lipoprotein lipid response to the National Cholesterol Education Program step II diet by hypercholesterolemic and combined hyperlipidemic women and men Arteriosclerosis, Thrombosis and Vascular Biology. 199717(2)375 382
52 Stefanick ML, Mackey S, Sheehan M, Ellsworth N, Haskell WL, Wood PD Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol N Engl J Med. 1998339(1)12 20
53 Andrews TC, Raby K, Barry J, et al Effect of cholesterol reduction on myocardial ischemia in patients with coronary disease Circulation. 199795(2)324 328
54 Schlierf G, Schuler G, Hambrecht R, et al. Treatment of coronary heart disease by diet and exercise. J Cardiovasc Pharmacol.
55 LaRosa JC, Cleary P, Muesing RA, Gorman P, Hellerstein HK, Naughton J Effect of long-term moderate physical exercise on plasma lipoproteins: The National Exercise and Heart Disease Project Arch Intern Med. 19821422269 2274
56 Kromhout D, Arntzenius AC, van der Velde EA. Diet and coronary heart disease: the Leiden Intervention Trial. Bibl Nutr Dieta. 1986:119-120.
57 Levy RI Report on the Lipid Research Clinic trials Eur Heart J. 19878(Suppl E)45 53
58 Heller RF, Elliott H, Bray AE, Alabaster M Reducing blood cholesterol levels in patients with peripheral vascular disease: dietitian or diet fact sheet? Med J Aust. 1989151(10)566 568
59 Brown G, Albers JJ, Fisher LD, et al Regression of coronary artery disease as a result of intensive lipid-lowering therapy in men with high levels of apolipoprotein B N Engl J Med. 1990323(19)1289 1298
60 Singh RB, Rastogi SS, Sircar AR, Mehta PJ, Sharma KK Dietary strategies for risk-factor modification to prevent cardiovascular diseases Nutr. 19917(3)210 214
61 Waters D, Higginson L, Gladstone P, Boccuzzi SJ, Cook T, Lesperance J Effects of cholesterol lowering on the progression of coronary atherosclerosis in women: A Canadian Coronary Atherosclerosis Intervention Trial (CCAIT) substudy Circulation. 199592(9)2404 2410
62 Niebauer J, Hambrecht R, Velich T, et al Attenuated progression of coronary artery disease after 6 years of multifactorial risk intervention: role of physical exercise Circulation. 1997962534 2541
63 Gorder DD, Dolecek TA, Coleman GG, et al Dietary intake in the Multiple Risk Factor Intervention Trial (MRFIT): nutrient and food group changes over 6 years J Am Diet Assoc. 198686(6)744 751
64 Lovibond SH, Birrell PC, Langeluddecke P Changing coronary heart disease risk-factor status: the effects of three behavioral programs J Behav Med. 19869(5)415 437
65 Laitinen JH, Ahola IE, Sarkkinen ES, Winberg RL, Harmaakorpi-Iivonen PA, Uusitupa MI Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus J Am Diet Assoc. 199393(3)276 283
66 Laitinen J, Uusitupa M, Ahola I, Siitonen O Metabolic and dietary determinants of serum lipids in obese patients with recently diagnosed non-insulin-dependent diabetes Ann Med. 199426(2)119 124
67 Schmidt LE, Cox MS, Buzzard IM, Cleary PA Reproducibility of a comprehensive diet history in the Diabetes Control and Complications Trial: The DCCT Research Group J Am Diet Assoc. 199494(12)1392 1397
68 Bovbjerg VE, McCann BS, Brief DJ, et al Spouse support and long-term adherence to lipid-lowering diets Am J Epidemiol. 1995141(5)451 460
69 Cambien F, Richard JL, Ducimetiere P, Warnet JM, Kahn J The Paris Cardiovascular Risk Factor Prevention Trial: Effects of two years of intervention in a population of young men J Epidemiol Community Health. 198135(2)91 97
70 Rose G, Heller RF, Pedoe HT, Christie DG UK Heart disease prevention project: a randomised controlled trial in industry BMJ. 1980280(6216)747 751
71 Walter HJ, Hofman A, Vaughan RD, Wynder EL Modification of risk factors for coronary heart disease: Five-year results of a school-based intervention trial N Engl J Med. 1988318(17)1093 1100
72 Schectman JM, Stoy DB, Elinsky EG Association between physician counseling for hypercholesterolemia and patient dietary knowledge Am J Prev Med. 199410(3)136 139
73 Byers T, Mullis R, Anderson J, et al The costs and effects of a nutritional education program following work-site cholesterol screening Am J Public Health. 199585(5)650 655
74 Garcia A, Gutierrez JM, Fernandez S, Aparicio J, Menendez-Patterson A Dietary intervention in a hypercholesterolemic school-aged population from Northern Spain Rev Esp Fisiol. 199652(1)49 58
75 Murray DM, Kurth C, Mullis R, Jeffery RW Cholesterol reduction through low-intensity interventions: results from the Minnesota Heart Health Program Prev Med. 199019(2)181 189
76 Kinlay S, Heller RF Effectivenesss and hazards of case finding for a high cholesterol concentration BMJ. 19903001545 1547
77 Milne RM, Mann JI, Chisholm AW, Williams SM Long-term comparison of three dietary prescriptions in the treatment of NIDDM Diabetes Care. 199417(1)74 80
78 Elmer PJ, Grimm RJ, Laing B, et al Lifestyle intervention: results of the Treatment of Mild Hypertension Study (TOMHS) Prev Med. 199524(4)378 388
79 Turpeinen O, Karvonen MJ, Pekkarinen M, Miettinen M, Elosuo R, Paavilainen E Dietary prevention of coronary heart disease: the Finnish Mental Hospital Study Int J Epidemiol. 19798(2)99 118
80 Lee-Han H, Cousins M, Beaton M, et al Compliance in a randomized clinical trial of dietary fat reduction in patients with breast dysplasia Am J Clin Nutr. 198848(3)575 586
81 Boyd NF, Cousins M, Beaton M, Kriukov V, Lockwood G, Tritchler D Quantitative changes in dietary fat intake and serum cholesterol in women: results from a randomized, controlled trial Am J Clin Nutr. 199052(3)470 476
82 Insull WJ, Henderson MM, Prentice RL, et al Results of a randomized feasibility study of a low-fat diet Arch Intern Med. 1990150(2)421 427
83 Parker JO, Vankoughnett KA, Farrell B Nitroglycerin lingual spray: clinical efficacy and dose-response relation Am J Cardiol. 1986571 5
84 Johannesson M, Borgquist L, Jonsson B, Lindholm LH The cost effectiveness of lipid lowering in Swedish primary health care: The CELL Study Group J Intern Med. 1996240(1)23 29
85 Davidson M, McKenney J, Stein E, et al Comparison of one-year efficacy and safety of atorvastatin versus lovastatin in primary hypercholesterolemia: Atorvastatin Study Group I Am J Cardiol. 199779(11)1475 1481
86 Anderson JW, Garrity TF, Wood CL, Whitis SE, Smith BM, Oeltgen PR Prospective, randomized, controlled comparison of the effects of low-fat and low-fat plus high-fiber diets on serum lipid concentrations Am J Clin Nutr. 199256887 894
87 Neil HA, Silagy CA, Lancaster T, et al Garlic powder in the treatment of moderate hyperlipidaemia: a controlled trial and meta-analysis J Royal Coll Physicians London. 199630(4)329 334
88 Walsh JM, Grady D Treatment of hyperlipidemia in women JAMA. 1995274(14)1152 1158 7563487
89 Corr LA, Oliver MF The low fat/low cholesterol diet is ineffective Eur Heart J. 199718(1)18 22
90 Dayton Seal: A controlled clinical trial of a diet high in unsaturated fat in preventing complications of atherosclerosis Circulation. 196940 (Suppl II)1 63
91 , Redman, WA.
92 , Redman, WA.
93 , Redman, WA.
94
95 Pignone MP, Phillips CJ, Mulrow CD Primary prevention of coronary heart disease with pharmacological lipid-lowering therapy: a meta-analysis of randomized trials BMJ. 2000321983 986
96 Lipid Research Clinics Program The Lipid Research Clinics Coronary Primary Prevention Trial results, II: The relationship of reduction in incidence of coronary heart disease to cholesterol lowering JAMA. 1984251(3)365 374
97 Frick M, Elo O, Haapa K, et al Helsinki Heart Study: primary-prevention trial with gemfibrozil in middle-aged men with dyslipidemia N Engl J Med. 19873171237 1245
98 Shepherd J, Cobbe SM, Ford I, et al Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia: West of Scotland Coronary Prevention Study Group N Engl J Med. 1995333(20)1301 1307
99 Downs JR, Clearfield M, Weis S, et al Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS, Air Force/Texas Coronary Atherosclerosis Prevention Study JAMA. 1998279(20)1615 1622
100 Elkeles RS, Diamond JR, Poulter C, et al Cardiovascular outcomes in type 2 diabetes: A double-blind placebo-controlled study of bezafibrate: the St Diabetes Care. 199821641 648
101 Mercuri M, Bond MG, Sirtori CR, et al Pravastatin reduces carotid intima-media thickness progression in an asymptomatic hypercholesterolemic mediterranean population: the Carotid Atherosclerosis Italian Ultrasound Study Am J Med. 1996101627 634
102 Byington RP, Evans GW, Espeland MA, et al. Effects of lovastatin and warfarin on early carotid atherosclerosis, sex-specific analyses: Asymptomatic Carotid Artery Progression Study (ACAPS) Research Group. Circulation.
103 The WOSCOPS Study Group WoSCPS. Screening experience and baseline characteristics in the West of Scotland Coronary Prevention Study Am J Cardiol. 199576(7)485 491
104 Downs JR, Beere PA, Whitney E, et al Design & rationale of the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS) Am J Cardiol. 199780287 293
105 Hebert PR, Gaziano JM, Chan KS, Hennekens CH Cholesterol lowering with statin drugs, risk of stroke, and total mortality: An overview of randomized trials JAMA. 1997278313 321
106 Elkeles RS, Diamond JR, Poulter C, et al Cardiovascular outcomes in type 2 diabetes: A double-blind placebo-controlled study of bezafibrate: the St Diabetes Care. 199821641 648
107 Hebert PR, Gaziano JM, Chan KS, Hennekens CH Cholesterol lowering with statin drugs, risk of stroke, and total mortality: An overview of randomized trials JAMA. 1997278313 321
108 Warshafsky S, Packard D, Marks SJ, et al Efficacy of 3-Hydroxy-3-Methylglutaryl Coenzyme A reductase inhibitors for prevention of stroke J Gen Intern Med. 199914763 774
109 Lambert M, Lupien PJ, Gagne C, et al Treatment of familial hypercholesterolemia in children and adolescents: effect of lovastatin: Canadian Lovastatin in Children Study Group Pediatrics. 199697(5)619 628
110 Knipscheer HC, Boelen CC, Kastelein JJ, et al Short-term efficacy and safety of pravastatin in 72 children with familial hypercholesterolemia Pediatr Res. 199639(5)867 871
111 Stein EA, Illingworth DR, Kwiterovich PO Jr, et al Efficacy and safety of lovastatin in adolescent males with heterozygous familial hypercholesterolemia: a randomized controlled trial JAMA. 1999281137 144
112 Tonstad S, Knudtzon J, Sivertsen M, Refsum H, Ose L Efficacy and safety of cholestyramine therapy in peripubertal and prepubertal children with familial hypercholesterolemia J Pediatrics. 199612942 49
113 Anonymous. 1998 in Review: The industry chalks up a banner year. Medical Marketing and Media.
114 Smith GD Low blood cholesterol and non-atherosclerotic disease mortality: where do we stand? Eur Heart J. 199718(1)6 9
115 Law MR, Thompson SG, Wald NJ Assessing possible hazards of reducing serum cholesterol BMJ. 1994308373 379
116 Pedersen TR, Kjekshus J, Berg K, et al Cholesterol lowering and the use of healthcare resources Circulation. 199693(10)1796 1802
117 Jeppesen J, Gaist D, Smith T, Sindrup SH Statins and peripheral neuropathy Eur J Clin Pharmacol. 199954835 838
118 Pierce LR, Wysowski DK, Gross TP Myopathy and rhabdomyolysis associated with lovastatin-gemfibrozil combination therapy JAMA. 1990264(1)71 75
119 Wallace CS, Mueller BA Lovastatin-induced rhabdomyolysis in the absence of concomitant drugs Ann Pharmacother. 199226(2)190 192
120 Contermans J, Smit JW, Bar PR, Erkelens DW A comparison of the effects of simvastatin and pravastatin monotherapy on muscle histology and permeability in hypercholesterolaemic patients Brit J Clin Pharmacol. 199539(2)135 141
121 Hill C, Zeitz C, Kirkham B Dermatomyositis with lung involvement in a patient treated with simvastatin Austr N Z J Med. 199525(6)745 746
122 Scalvini T, Marocolo D, Cerudelli B, Sleiman I, Balestrieri GP, Giustina G Pravastatin-associated myopathy: Report of a case Recenti Prog Med. 199586(5)198 200
123 Chu PH, Chen WJ, Chiang CW, Lee YS Rhabdomyolysis, acute renal failure and hepatopathy induced by lovastatin monotherapy Jpn Heart J. 199738(4)541 545
124 Giordano N, Senesi M, Mattii G, Battisti E, Villanova M, Gennari C Polymyositis associated with simvastatin Lancet. 1997349(9065)1600 1601
125 Wicher-Muniak E, Zmudka K, Dabros W, Dudek D, Stachura J Simvastatin-induced myopathy in a patient treated for hypercholesterolemia: Morphological aspects Polish Journal of Pathology. 199748(1)69 74
126 Hartleb M, Rymarczyk G, Januszewski K Acute cholestatic hepatitis associated with pravastatin Am J Gastroenterol. 1999941388 1390
127 Laties AM, Shear CL, Lippa EA, et al Expanded clinical evaluation of lovastatin (EXCEL) study results, II: Assessment of the human lens after 48 weeks of treatment with lovastatin Am J Cardiol. 199167(6)447 453
128 Harris ML, Bron AJ, Brown NA, et al Absence of effect of simvastatin on the progression of lens opacities in a randomised placebo controlled study: Oxford Cholesterol Study Group Brit J Ophthalmol. 199579(11)996 1002
129 Newman TB, Hulley SB Carcinogenicity of lipid-lowering drugs JAMA. 199627555 60 8531288
130 Boumendil E, Tubert-Bitter P Depression-induced absenteeism in relation to antihyperlipidemic treatment: a study using GAZEL cohort data Epidemiolology. 19956322 325
131 Cutler N, Sramek J, Veroff A, Block G, Stauffer L, Lines C Effects of treatment with simvastatin and pravastatin on cognitive function in patients with hypercholesterolaemia Brit J Clin Pharmacol. 199539(3)333 336
132 Davidson KW, Reddy S, McGrath P, Zitner D, MacKeen W Increases in depression after cholesterol-lowering drug treatment Behav Med. 199622(2)82 84
133 Delva NJ, Matthews DR, Cowen PJ Brain serotonin (5-HT) neuroendocrine function in patients taking cholesterol-lowering drugs Biol Psychiatry. 199639(2)100 106
134 Golomb BA Cholesterol and violence: is there a connection? Ann Intern Med. 1998128478 487
135 Sridhar MK, Abdulla A. Fatal lupus-like syndrome and ARDS induced by fluvastatin. Lancet.
136 Manson JM, Freyssinges C, Ducrocq MB, Stephenson WP Postmarketing surveillance of lovastatin and simvastatin exposure during pregnancy Reprod Toxicol. 199610(6)439 446
137 Azzarito C, Boiardi L, Vergoni W, Zini M, Portioli I Testicular function in hypercholesterolemic male patients during prolonged simvastatin treatment Horm Metab Res. 199628(4)193 198
138 IMS Health. IMS Health reveals factors influencing cholesterol treatment: findings have implications for patient managementhttp://www.imshealth.com/html/in_arc/06_01_98_24.htm
139 Gibbons LW, Gonzalez V, Gordon N, Grundy S The prevalence of side effects with regular and sustained-release nicotinic acid Am J Med. 199599(4)378 385
140 Cholesterol Treatment Trialists' (CTT) Collaboration. Protocol for a prospective collaborative overview of all current and planned randomized trials of cholesterol treatment regimens Am J Cardiol. 1995751130 1134
141 Blane GF Comparative toxicity and safety profile of fenofibrate and other fibric acid derivatives Am J Med. 19878326 36
142 Huttunen JK, Heinonen OP, Manninen V, et al The Helsinki Heart Study: an 8 J Intern Med. 199423531 39
143 McKenney JM, Proctor JD, Harris S, Chinchili VM A comparison of the efficacy and toxic effects of sustained- vs immediate-release niacin in hypercholesterolemic patients JAMA. 1994271(9)672 677
144 Roderick P, Ruddock V, Hunt P, Miller G A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk Brit J Gen Pract. 199747(414)7 12
145 Andrade SE, Walker AM, Gottlieb LK, et al Discontinuation of antihyperlipidemic drugs--do rates reported in clinical trials reflect rates in primary care settings? N Engl J Med. 19953321125 1131
146 Avorn J, Monette J, Lacour A, et al Persistence of use of lipid-lowering medications: a cross-national study JAMA. 19982791458 1462
147 Hooper L, Summerbell C.D., Higgins JPT, et al. Reduced or modified dietary fat for preventing cardiovascular disease.(Cochrane review).
148 Bakx JC, Stafleu A, van Staveren WA, van den Hoogen HJ, van Weel C. Long-term effect of nutritional counseling: a study in family medicine. Am J Clin Nutr.
149 Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: results of the OXCHECK study after one year BMJ. 1994308(6924)308 312
150 Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study BMJ. 1995310(6987)1099 1104
151 Baron JA, Gleason R, Crowe B, Mann JI Preliminary trial of the effect of general practice based nutritional advice Brit J Gen Pract. 199040(333)137 141
152 Lindholm LH, Ekbom T, Dash C, Eriksson M, Tibblin G, Schersten B The impact of health care advice given in primary care on cardiovascular risk: CELL Study Group BMJ. 1995310(6987)1105 1109
153 Pyke SD, Wood DA, Kinmouth AL, Thompson SG Change in coronary risk and coronary risk factor levels in couples following lifestyle intervention Arch Fam Med. 19976354 360
154 Tang JL, Armitage JM, Lancaster T, Silagy CA, Fowler GH, Neil HAW Systematic review of dietary intervention trials to lower blood total cholesterol in free-living subjects BMJ. 1998316(7139)1213 1220
155 Brunner E, White I, Thorogood M, Bristow A, Curle D, Marmot M Can dietary interventions change diet and cardiovascular risk factors? A meta-analysis of randomized controlled trials Am J Public Health. 199787(9)1415 1422
156 Denke MA Cholesterol-lowering diets: A review of the evidence Arch Intern Med. 199515517 26
157 Multiple Risk Factor Intervention Trial Research Group. Multiple risk factor intervention trial, risk factor changes and mortality results JAMA. 19822481465 1477
158 World Health Organisation European Collaborative Group. European collaborative trial of multifactorial prevention of coronary heart disease: final report on the 6-year results Lancet. 19861869 872
159 Hjermann I, Velve Byre K, Holme I, Leren P Effect of diet and smoking intervention on the incidence of coronary heart disease: Report from the Oslo Study Group of a randomised trial in healthy men Lancet. 198121303 1310
160 Wilhelmsen L, Berglund G, Elmfeldt D, et al The multifactor primary prevention trial in Goteborg, Sweden Eur Heart J. 19867279 288
161 Miettinen TA, Huttunen JK, Naukkarinen V, et al Multifactorial primary prevention of cardiovascular diseases in middle-aged men: Risk factor changes, incidence, and mortality JAMA. 19852542097 2102
162 Holme I, Hjermann I, Helgeland A, Leren P The Oslo Study: diet and antismoking advice, additional results from a 5-year primary preventive trial in middle-aged men Prev Med. 198514(3)279 292
163 Ebrahim S, Smith GD Systematic review of randomised controlled trials of multiple risk factor interventions for preventing coronary heart disease BMJ. 1997314(7095)1666 1674
164 Robertson I, Phillips A, Mant D, et al Motivational effect of cholesterol measurement in general practice health checks Brit J Gen Pract. 199242(364)469 472
165 Elton PJ, Ryman A, Hammer M, Page F Randomised controlled trial in northern England of the effect of a person knowing their own serum cholesterol concentration J Epidemiol Community Health. 199448(1)22 25
166 Hanlon P, McEwen J, Carey L, et al Health checks and coronary risk: further evidence from a randomised controlled trial BMJ. 1995311(7020)1609 1613
167 Strychar IM, Champagne F, Ghadirian P, Bonin A, Jenicek M, Lasater TM Impact of receiving blood cholesterol test results on dietary change Am J Prev Med. 199814(2)103 110
168 National Heart, Lung and Blood Institute National Heart, Lung, and Blood Institute recommendations on lipoprotein measurementhttp://www.nhlbi.nih.gov/health/prof/heart/chol/lipoprot.pdf
169 McDowell MA, Briefel RR, Alaimo K, et al. Energy and Macronutrient Intakes of Persons Ages 2 Months and Over in the United States: Third National Health and Nutrition Examination Survey, Phase 1, 1988-1991. Advance Data From Vital and Health Statistics, No. 255. 1994:1-24.
170 Dietary Intervention Study in Children (DISC) Collaborative Research Group. Efficacy and safety of lowering dietary intake of fat and cholesterol in children with elevated low-density lipoprotein cholesterol JAMA. 1995273(18)1429 1435
171 Kwiterovich PJ, Barton BA, McMahon RP, et al Effects of diet and sexual maturation on low-density lipoprotein cholesterol during puberty: the Dietary Intervention Study in Children (DISC) Circulation. 199796(8)2526 2533
172 Obarzanek E, Hunsberger SA, Van Horn L, et al Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC) Pediatrics. 1997100(1)51 59
173 Tershakovec AM, Jawad AF, Stallings VA, et al Growth of hypercholesterolemic children completing physician-initiated low-fat dietary intervention J Pediatrics. 1998133(1)28 34
174 Niinikoski H, Viikari J, Ronnemaa T, et al Prospective randomized trial of low-saturated-fat, low-cholesterol diet during the first 3 years of life: The STRIP baby project Circulation. 199694(6)1386 1393
175 Lapinleimu H, Viikari J, Jokinen E, et al Prospective randomised trial in 1062 infants of diet low in saturated fat and cholesterol Lancet. 1995345(8948)471 476
176 Lagstrom H, Jokinen E, Seppanen R, et al Nutrient intakes by young children in a prospective randomized trial of a low-saturated fat, low-cholesterol diet: The STRIP Baby Project (Special Turku Coronary Risk Factor Intervention Project for Babies) Arch Pediatr Adolesc Med. 1997151(2)181 188
177 Luepker RV, Perry CL, McKinlay SM, et al Outcomes of a field trial to improve children's dietary patterns and physical activity: The Child and Adolescent Trial for Cardiovascular Health JAMA. 1996275(10)768 776
178 Lifshitz F, Moses N Growth failure: A complication of dietary treatment of hypercholesterolemia Am J Dis Child. 1989143537 542
179 Nicklas TA, Webber LS, Koschak M, Berenson GS Nutrient adequacy of low fat intakes for children: the Bogalusa Heart Study Pediatrics. 199289221 228
180 Miller TD, Balady GJ, Fletcher GF Exercise and its role in the prevention and rehabilitation of cardiovascular disease Ann Behav Med. 199719(3)220 229
181 Tran ZV, Weltman A Differential effects of exercise on serum lipid and lipoprotein levels seen with changes in body weight: A meta-analysis JAMA. 1985254919 924
182 Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S Behavioural counselling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial BMJ. 1999319943 947
183 Burr ML, Fehily AM, Gilbert JF, et al Effects of changes in fat, fish, and fibre intakes on death and myocardial reinfarction: diet and reinfarction trial (DART) Lancet. 19892757 61
184 de Lorgeril M, Salen P, Martin JL, Monjaud I, Delaye J, Mamelle N Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: final report of the Lyon Diet Heart Study Circulation. 199999779 785
185 Frantz ID Jr, Dawson EA, Ashman PL, et al Test of effect of lipid lowering by diet on cardiovascular risk: The Minnesota Coronary Survey Arterioscl. 19899129 135
186 Clarke R, Frost C, Collins R, Appleby P, Peto R Dietary lipids and blood cholesterol: quantitative meta-analysis of metabolic ward studies BMJ. 1997314112 117
187 Srinivasan SR, Berenson GS. Childhood lipoprotein profiles and implications for adult coronary artery disease: the Bogalusa Heart Study. Am J Med Sci.
188 Berenson GS, Frank GC, Hunter SM, Srinivasan SR, Voors AW, Webber LS Cardiovascular risk factors in children: Should they concern the pediatrician? Am J Dis Child. 1982136855 862
189 Webber LS, Srinivasan SR, Wattigney WA, Berenson GS Tracking of serum lipids and lipoproteins from childhood to adulthood: The Bogalusa Heart Study Am J Epidemiol. 1991133884 899
190 Pathobiological Determinants of Atherosclerosis in Youth (PDAY) Research Group. Relationship of atherosclerosis in young men to serum lipoprotein cholesterol concentrations and smoking: A preliminary report from the Pathobiological Determinants of Atherosclerosis in Youth (PDAY) Research Group JAMA. 19902643018 3024
191 Lauer RM, Clarke WR Use of cholesterol measurements in childhood for the prediction of adult hypercholesterolemia: The Muscatine Study JAMA. 19902643034 3038
192 Health Care Financing Administrationhttp://www.hcfa.gov/stats/pufiles.htm
193 Anonymous Ambulatory Health Care Data pagehttp://www.cdc.gov/nchswww/about/major/ahcd/ahcd1.htm
194 Kannel WB. Range of serum cholesterol values in the population developing coronary artery disease. Am J Cardiol.
195 Williams RR, Hunt SC, Schumacher MC, et al Diagnosing heterozygous familial hypercholesterolemia using new practical criteria validated by molecular genetics Am J Cardiol. 199372171 176
196 Slack J Risks of ischaemic heart-disease in familial hyperlipoproteinaemic states Lancet. 196921380 1382 4188273
197 Stone NJ, Levy RI, Fredrickson DS, Verter J Coronary artery disease in 116 kindred with familial type II hyperlipoproteinemia Circulation. 197449476 488
198 Diller PM, Huster GA, Leach AD, Laskarzewski PM, Sprecher DL Definition and application of the discretionary screening indicators according to the National Cholesterol Education Program for Children and Adolescents J Pediatr. 1995126(3)345 352
199 Dennison BA, Kikuchi DA, Srinivasan SR, Webber LS, Berenson GS Parental history of cardiovascular disease as an indication for screening for lipoprotein abnormalities in children J Pediatr. 1989115186 194
200 Primrose ED, Savage JM, Boreham CA, Cran GW, Strain JJ Cholesterol screening and family history of vascular disease Arch Dis Child. 199471(3)239 242
201 Griffin TC, Christoffel KK, Binns HJ, McGuire PA Family history evaluation as a predictive screen for childhood hypercholesterolemia Ann N Y Acad Sci. 1991623443 444
202 Garcia RE, Moodie DS Routine cholesterol surveillance in childhood Pediatrics. 198984(5)751 755
203 Steiner NJ, Neinstein LS, Pennbridge J Hypercholesterolemia in adolescents: effectiveness of screening strategies based on selected risk factors Pediatrics. 19918(2)269 275
204 Resnicow K, Cross D Are parents' self-reported total cholesterol levels useful in identifying children with hyperlipidemia? An examination of current guidelines Pediatrics. 199392347 353
205 Benuck I, Gidding SS, Donovan M, Traisman ES, Traisman HS Usefulness of parental serum total cholesterol levels in identifying children with hypercholesterolemia Prev Cardiol. 199269(8)713 717
206 Cooper GR, Myers GL, Smith SJ, Schlant RC Blood Lipid Measurements: Variations and Practical Utility JAMA. 19922671652 1660
207 Caudill SP, Cooper GR, Smith SJ, Myers GL Assessment of current National Cholesterol Education Program guidelines for total cholesterol triglyceride, HDL-cholesterol, and LDL-cholesterol measurements Clin Chem. 1998441650 1658
208 Gillman MW, Cupples LA, Moore LL, Ellison RC Impact of within-person variability on identifying children with hypercholesterolemia: Framingham Children's Study J Pediatr. 1992121342 347
209 Grover SA, Coupal L, Hu XP Identifying adults at increased risk of coronary disease: How well do the current cholesterol guidelines work? JAMA. 1995274(10)801 806
210 Kinosian B, Glick H, Garland G Cholesterol and coronary heart disease: predicting risks by levels and ratios Ann Intern Med. 1994121641 647
211 Avins AL, Browner WS Improving the prediction of coronary heart disease to aid in the management of high cholesterol levels: what a difference a decade makes JAMA. 1998279445 449
212 Caggiula AW, Watson JE, Milas NC, Olson MB, Kuller LH, Orchard TJ Evaluating the efficacy of the National Cholesterol Education Program adult treatment guidelines: cholesterol lowering intervention program Prev Med. 199524(5)485 491
213 Lannon CM, Earp JA Parents' behavior and attitudes toward screening children for high serum cholesterol levels Pediatrics. 1992891159 1163
214 Bachman RP, Schoen EJ, Stembridge A, Jurecki ER, Imagire RS Compliance with childhood cholesterol screening among members of a prepaid health plan Am J Dis Child. 1993147382 385
215 Grover SA, Lowensteyn I, Esrey KL, Steinert Y, Joseph L, Abrahamowicz M Do doctors accurately assess coronary risk in their patients? Preliminary results of the coronary health assessment study BMJ. 1995310975 978
216 Davis KC, Cogswell ME, Rothenberg SL, Koplan JP Lipid screening in a managed care population Public Health Rep. 1998113(4)346 350
217 Wallis EJ, Ramsay LE, Haq IU, et al Coronary and cardiovascular risk estimation for primary prevention: validation of a new Sheffield table in the 1995 Scottish health survey population BMJ. 2000320671 676
218 Isles C, Ramsay L, Wallis E, Haq I, Ritchie L Whom to treat in primary prevention? Proc Royal Coll Physicians Edinburgh. 19992916 25
219 Ramsay LE, Haq IU, Jackson PR, Yeo WW, Pickin DM, Payne JN Targeting lipid-lowering drug therapy for primary prevention of coronary disease: an update Sheffield table Lancet. 1996348387 388
220 Hingorani AD, Vallance P A simple computer program for guiding management of cardiovascular risk factors and prescribing BMJ. 1999318101 105
221 Lowensteyn I, Joseph L, Levinton C, Abrahamowicz M, Steinert Y, Grover S Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS) Prev Med. 199827730 737
222 Austin MA, Hokanson JE, Edwards KL. Hypertriglyceridemia as a cardiovascular risk factor. Am J Cardiol.
223 Avins AL, Neuhaus JM Do triglycerides provide meaningful information about heart disease risk? Arch Intern Med. 20001601937 44
224 Harjai KJ Potential new cardiovascular risk factors: left ventricular hypertrophy, homocysteine, lipoprotein (a), triglycerides, oxidative stress, and fibrinogen Ann Intern Med. 1999131376 386
225 Pahor M, Elam MB, Garrison RJ, Kritchevsky SB, Applegate WB Emerging noninvasive biochemical measures to predict cardiovascular risk Arch Intern Med. 1999159237 245
226 Ridker PM Evaluating novel cardiovascular risk factors: can we better predict heart attacks? Ann Intern Med. 1999130933 937
227 Haynes RB, Sackett DL, Taylor DW, Gibson ES, Johnson AL Increased absenteeism from work after detection and labeling of hypertensive patients N Engl J Med. 1978299741 744
228 Brett AS Psychologic effects of the diagnosis and treatment of hypercholesterolemia: lessons from case studies Am J Med. 199191642 647
229 Tijmstra T The psychological and social implications of serum cholesterol screening Int J Risk Safety Med. 1990129 44
230 Havas S, Reisman J, Hsu L, Koumjian L Does cholesterol screening result in negative labeling effects? Results of the Massachusetts Model Systems for Blood Cholesterol Screening Project Arch Intern Med. 1991151113 119
231 Irvine MJ, Logan AG Is knowing your cholesterol number harmful? J Clin Epidemiol. 199447(2)131 145
232 Rosenberg E, Lamping DL, Joseph L, Pless IB, Franco ED Cholesterol screening of children at high risk: behavioural and psychological effects CMAJ. 1997156(4)489 496
233 Hueston WJ, Spencer E, Kuehn R Differences in the frequency of cholesterol screening in patients with Medicaid compared with private insurance Arch Fam Med. 19954(4)331 334
234 Stein AD, Lederman RI Prevention-oriented life styles and diffusion of cholesterol screening and awareness: Massachusetts behavioral risk factor survey, 1987-1991 J Clin Epidemiol. 199649(3)305 311
235 Lewis SJ, Sacks FM, Mitchell JS, et al Effect of pravastatin on cardiovascular events in women after myocardial infarction: the cholesterol and recurrent events (CARE) trial J Am Coll Cardiol. 199832(1)140 146
236 Hulley SB, Newman TB, Grady D, Garber AM, Baron RB, Browner WS Should we be measuring blood cholesterol levels in young adults? JAMA. 1993269(11)1416 1419
237 LaRosa JC, Pearson TA Cholesterol screening guidelines consensus, evidence, and the departure from common sense Circulation. 1997951651 1653
238 Scientific Steering Committee on behalf of the Simon Broome Register Group. Risk of fatal coronary heart disease in familial hypercholesterolaemia BMJ. 1991303893 896
239 Klag MJ, Ford DE, Mead LA, et al Serum cholesterol in young men and subsequent cardiovascular disease N Engl J Med. 1993328313 318
240 Cleeman JI, Grundy SM National Cholesterol Education Program recommendations for cholesterol testing in young adults Circulation. 1997951646 1650
241 Kannel WB, Schatzkin A. Sudden death: lessons from subsets in population studies. J Am Coll Cardiol.
242 Law MR, Wald NJ, Thompson SG By how much and how quickly does reduction in serum cholesterol concentration lower risk of ischaemic heart disease? BMJ. 1994308367 372
243 Jacobson TA, Chin MM, Curry CL, et al Efficacy and safety of pravastatin in African Americans with primary hypercholesterolemia Arch Intern Med. 1995155(17)1900 1906