# Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency for Healthcare Research and Quality (Task No. 3 to support the US Preventive Services Task Force). We acknowledge the ongoing guidance and assistance of David Atkins, M.D., M.P.H., Director of the Clinical Preventive Services program at AHRQ, Dana Best, M.D., the Task Order Officer for this project, and Jacqueline Besteman, J.D., M.A., the Program Officer in the Center for Practice and Technology Assessment for the entire AHRQ Evidence-based Practice Center program.. We also acknowledge the assistance of Eve Shapiro, Managing Editor, under contract to the AHRQ Office of Health Care Information.

The investigators deeply appreciate the considerable support and contributions of faculty and staff from the University of North Carolina at Chapel Hill: Timothy S. Carey, M.D., M.P.H.; Co-Director of the RTI-UNC EPC; Russell P. Harris, M.D., M.P.H., Co-Director of the RTI-UNC EPC's Clinical Prevention Center; Anne Jackman, M.S.W.; Barbara E. Starrett, M.H.A.; Alyssa Wood, M.F.A., and Carol Krasnov. They are equally grateful to Linda Lux, M.P.A., Anjolie Idicula, B.A., and Sonya Sutton, B.S.P.H. of Research Triangle Institute for substantive project assistance and to Nicole Walker and Sheila White for, respectively, valuable contract assistance and superior secretarial support.

We appreciate the efforts of the following external peer reviewers who provided insightful and constructive suggestions for improvements in the systematic evidence review: Andy Avins, M.D., Department of Veterans Affairs (VA) Medical Center, San Francisco, CA; Robert Baron, M.D., University of California-San Francisco, San Francisco, Calif.; Warren Browner, M.D., for the American College of Physicians and American Society of Internal Medicine, VA Medical Center, San Francisco, Calif.; James Cleeman, M.D., National Heart, Lung and Blood Institute, National Institutes of Health, Bethesda, Md.; Theodore Ganiats, MD, for the American Academy of Family Practice, , University of California-San Diego, La Jolla, Calif.; Wayne Giles, M.D., M.S. ,Centers for Disease Control and Prevention, Atlanta, Ga.; Matthew Gillman, M.D., S.M., Harvard Medical School and Harvard Pilgrim Health Care, Boston, Mass., ; Jeffrey Harris, M.D., Centers for Disease Control and Prevention, Atlanta, Ga., ; Marc Jacobson, M.D., for the American Academy of Pediatrics, , Schneider Children's Hospital, New Hyde Park, NY; David Katz, MD, MPH, Yale University School of Public Health, New Haven, Conn.; Michel Labrecque, M.D., M.Sc., for the Canadian Task Force on Preventive Health Care, Universite Laval, Rimouski, Quebec, Canada; Haq Nawaz, MD, MPH, for the American College of Preventive Medicine, Yale-Griffin Prevention Research Center, Derby, Conn., ; Thomas Newman, M.D. M.P.H., University of California-San Francisco, San Francisco, Calif., ; Thomas Nolan, M.D., for the American College of Obstetricians and Gynecologists, , Louisiana State University, New Orleans, La., ; and Hanna Rubins, MD, from the Department of Verterans Affairs.