# Discussion

## Introduction to Key Issues

Chapter 3. and the Evidence Tables in Appendix 3 have systematically reviewed the evidence about drug, diet, and exercise therapy for lipid disorders and examined the performance of various strategies for screening. Table 10 presents a qualitative summary of our findings. This chapter summarizes the evidence about benefits and harms of treatment and screening for different demographic groups. We begin with the group in which the evidence is strongest (middle-aged men) and then consider postmenopausal middle-aged women, elderly men and women (more than 70 years of age), young adult men and premenopausal adult women, and finally adolescents and children.

Table 9. Features of Different Screening Strategies for Adults

Test | Reliability | Accuracy | Patient Acceptability | Feasibility for Providers
Nonfasting TC | Intermediate | Lower | Higher | Higher
Nonfasting TC/HDL | Lower | Intermediate | Higher | Intermediate
LDL/HDL ratio requires fasting TC, HDL, triglycerides | Higher | Intermediate | Lower | Intermediate
Nonfasting TC + HDL and NCEP guidelines | Intermediate | Intermediate | Intermediate | Lower
Nonfasting TC + HDL with calculation of Framingham risk | Intermediate | Higher | Intermediate | Lower

NOTE: TC = total cholesterol; HDL = high-density lipoproteins; LDL = low-density lipoproteins; NCEP = National Cholesterol Educational Panel.

Table 10. Ratings of Aggregate Internal Validity, Aggregate External Validity, and Coherence, and Overall Rating, for Three Key Questions

Subsidiary Questions | Aggregate Internal Validity | Aggregate External Validity | Coherence | Overall Rating
Key Question No. 1. Drug Therapy
Benefits | Good | Fair | Good | Good
Harms | Good (short term) Poor (long term) | Fair | Fair | Fair
Key Question No. 2. Diet Therapy
Benefits (overall) | Good | Fair | Fair | Fair
Primary care studies | Good | Good | Fair | Good
Large MRF trials of diet | Good | Fair | Poor | Fair
Trials of effect of learning cholesterol | Fair | Fair | Fair | Fair
Harms (overall) | Poor | Fair | Poor | Poor
Key Question No. 3. Screening
Reliability | Good | Good | Good | Good
Accuracy | Good | Fair | Good | Good
Acceptability | Poor | Poor | Poor | Poor
Feasibility | Poor | Fair | Poor | Poor
Harms | Fair | Fair | Poor | Poor

NOTE: See Appendix C for explanation of ratings. MRF = multiple risk factor.

The most important reason for screening is to identify patients with a lipid disorder who will benefit from treatment, whether such treatment is pharmacologic therapy or more intensive diet and exercise therapy (ie, more than the general population recommendations of a healthy diet low in saturated fat diet and moderate physical activity). The available screening tests appear to identify reliably abnormal lipid levels across the spectrums of age, gender, ethnicity, and risk for coronary heart disease (CHD). Several means exist to identify accurately those patients with increased risk of CHD events because of lipid abnormalities, age, or the presence of other risk factors.

Data from lipid treatment studies in primary and secondary prevention settings suggest that the relative reduction in risk for CHD events for a given amount of cholesterol reduction is similar for patient populations with different underlying levels of risk for CHD events. Because the relative risk reduction is similar, the absolute benefit of treatment is related to the underlying absolute risk of CHD in the group being treated.

### Areas of Controversy in Screening Policy

The decision to screen for lipid disorders is based on the balance between the potential benefits and the potential harms of screening and treatment. Among many other factors, this balance is affected by the probability of finding an abnormal lipid profile and the short-term and long-term risks of CHD in the population being considered. The harms of screening and treatment have not been as well studied but are generally independent of underlying CHD risk. Controversy continues, however, about how far to extrapolate the data beyond the populations studied in the large trials of treatment, how to value potential benefits and harms, and how much weight to put on surrogate measures of benefit and harm such as changes in serum total cholesterol (TC) or changes in serum creatinine kinase.

### Extrapolation to Other Populations

The currently available lipid treatment studies have enrolled primarily middle-aged men (up to age 70 years) of European descent. We have less evidence to inform fully the decision about screening and treatment of asymptomatic persons in other demographic groups. Some trial data are available for middle-aged women, but men and women who are young (younger than 45 years), elderly (older than 70 years), or of non-European descent have not been studied extensively in trials. Little data are available for children and adolescents. In such cases, we must consider whether to utilize indirect evidence, which includes extrapolating the results from primary prevention trials in middle-aged men and secondary prevention trials in women and the elderly and also using surrogate endpoints and observational data about potential benefits and harms. We currently have no evidence to suggest that such extrapolations are inappropriate for persons with levels of CHD risk similar to those in the primary prevention trials.

### Weighing Benefits and Harms and the Use of Surrogate Outcomes

Differences in the relative weights assigned to the various potential benefits and harms are another important issue. At least three benefits other than the short-term prevention of CHD events and mortality are possible: identifying persons at early and high risk for CHD because of severe lipid disorders; providing motivation and feedback to encourage behavioral change among young adults and children in order to modify the development of atherosclerosis and prevent future CHD events; and providing a better estimate of CHD risk for prognostication and to guide decisions about other interventions such as the intensity of blood pressure control, advice to avoid tobacco, or the use of aspirin chemoprophylaxis.

Screening and treatment are also associated with possible harms, such as the labeling effect and the identification of persons as being at high risk who will not actually go on to have CHD events (false-positives). These effects become especially important when considering screening among low-risk patient groups in whom the magnitude of benefit is small and may be canceled out or exceeded by the adverse consequences of screening and treatment. In each of these areas, we have only indirect evidence available to help guide decision-making. The way in which these potential outcomes are valued has important ramifications for screening policy.

Similarly, experts do not fully agree about which outcome variables are sufficient to demonstrate efficacy and effectiveness. Some argue that the ability to lower cholesterol is sufficient proof of efficacy, whereas others would require that changes in CHD mortality or even total mortality be demonstrated in trials.

### Costs

Because the relative risk reduction with drug therapy appears to be approximately the same over a wide spectrum of baseline risks, the decision about whom to treat requires consideration of cost-effectiveness and the proportion of all CHD events that can be prevented. Treating at a higher threshold of absolute risk increases cost-effectiveness at the expense of failing to prevent the large total number of CHD events that occur in lower-risk individuals. Conversely, treating at a lower threshold will prevent a greater proportion of total events but is less cost-effective. Strategies that employ global CHD risk assessment to determine whom to treat are more accurate and efficient but may also be less acceptable or feasible and thus more difficult to implement.

## Findings for Specific Population Groups

### Middle-aged Men

The evidence in favor of screening and treatment of lipid disorders is strongest for middle-aged men with elevated levels of low-density lipoprotein (LDL) cholesterol and moderate to high short-term risk of CHD events. The West of Scotland Coronary Prevention Study (WOSCOPS) study demonstrated that treating middle-aged men with elevated LDL cholesterol and a baseline risk of CHD events of about 1.5% per year decreases the relative risk of CHD events by 33% and total mortality by 22%. ^98^ The Air Force/Texas Coronary Atherosclerorsis Prevention Study (TexCAPS) showed that treating middle-aged men at increased risk because of low levels of high-density lipoprotein (HDL) decreased CHD events, although the absolute benefit was low and total mortality was not affected. ^99^ The populations in these studies appear similar to those found in primary care practice. The probability of finding abnormal lipids and sufficient CHD risk is high in this age group.

### Postmenopausal Women

TexCAPS was the only trial in our final set of primary prevention studies that enrolled postmenopausal women. In general, the women in TexCAPS appeared to have a relative risk reduction for first CHD events similar to that for men, but they had fewer CHD deaths relative to total CHD events and the trial was not powerful enough to examine total mortality effects in this lower-risk population. ^99^

Evidence from secondary prevention trials suggests that women will achieve reductions in total CHD events similar to those for men at a given level of risk. In the short term (up to 5 years), these total reductions take the form primarily of fewer nonfatal myocardial infarctions (MI) rather than fewer CHD deaths. ^14^ ^,^ ^15^ ^,^ ^88^ ^,^ ^235^ The effect on total mortality for women remains unclear: the Scandinavian Simvastatin Survival Study (4S) study found a relative risk of 1.16 (95% confidence interval [CI], 0.68, 1.99) with drug therapy. ^14^ Data on total mortality for women have not yet been published in the other major trials of secondary prevention or primary prevention, and we have insufficient longitudinal data to measure the long-term effects of event reduction on total and CHD mortality.

Thus, reducing lipid levels appears to be effective in reducing CHD events in postmenopausal women with abnormal lipids, but the magnitude of that effect appears smaller, at least in part because middle-aged women with lipid disorders are at lower absolute risk than middle-aged men. Accurate global risk assessment is important, because women tend to have higher TC levels but lower CHD risk than men of similar ages. Ongoing trials such as the Women's Health Initiative will help to better define the effectiveness of lipid-lowering therapy in women.

### Elderly Men and Women

Few elderly persons (older than 70 years of age) have been studied in primary prevention trials, and some epidemiological studies have questioned the strength of the association between cholesterol and CHD among elderly patients (see Chapter 1.). However, data from the TexCAPS, Cholesterol and Recurrent Events Study, and Long-Term Intervention with Pravastatin in Ischemic Disease trials suggest that lipid lowering is as effective, or more effective, in older patients. ^11^ ^,^ ^15^ ^,^ ^17^ Older persons are otherwise at high levels of absolute risk of CHD events, so lipid-lowering therapy is likely to be effective, assuming that their risk of competing causes of mortality is not too high (ie, that their life expectancy is sufficient to allow them to realize the benefits of therapy).

### Young Men and Premenopausal Women

The benefits of screening for and treating lipid disorders in young adult men (ages 20 to 35 years) and premenopausal women (ages 20 to 45 years) are controversial. ^236^ ^,^ ^237^ The 2 main potential reasons for screening and treating lipid disorders in these populations are (1) identifying and treating with diet or drug therapy the small proportion of persons at immediate risk for CHD and (2) identifying persons at future risk for CHD events and treating them now to modify (ie, reduce) their future risk.

## Rationales for Screening and Treating Young Adults

### Identifying and treating those at risk of CHD events at an early age

With regard to the first rationale for screening and treatment (reduction of immediate risk), young adults in general are at very low absolute risk of CHD events. Even if we assume that lipid-lowering therapy in these groups reduces risk to the same or greater extent that it does in middle-aged adults, the benefits in terms of absolute risk reduction are low.

Universal screening of young adults has also been considered as a means of identifying and treating the small number of patients with severe, often genetic, lipid disorders who are at risk for premature CHD and who would not be recognized on the basis of either a family history of early CHD events or lipid abnormalities or the personal presence of multiple other CHD risk factors. If unrecognized, some patients with severe lipid disorders may have CHD events before universal screening at age 35 or 45 years. As we described in Chapter 3., familial hypercholesterolemia (FH) occurs in about 1 in 500 persons. Estimates of the gender-specific percentages of persons with this disorder who would have CHD events in the absence of recognition and treatment before ages 35 and 45 years, respectively, are 5% and 15% for men and 10% and 15% for women. ^196^ ^,^ ^197^ The proportion of young adults with severe lipid disorders and with no family history of early CHD events or personal history of multiple CHD risk factors appears to be 50% or less. ^238^ The proportion who also have no family history of extreme cholesterol levels may be even smaller.

### Treating to prevent future CHD risk

The burden of CHD events occurring in men who are 20 to 35 years of age and women who are 20 to 45 years of age is small. Thus, the decision to screen at those ages depends on whether identifying and treating young adults will reduce future CHD events more effectively than waiting until age 35 years in men and age 45 years in women. The crucial issue is whether beginning treatment of those persons with lipid abnormalities at a young age is more effective than waiting until later.

High TC levels in young adults are clearly predictive of higher rates of future CHD events in middle age. Data from a cohort of Johns Hopkins University medical students show that the relative risk of future CHD events and CHD mortality among those men with TC at the 75th percentile was 2 times greater than the relative risk among those at the 25th percentile. ^239^ The crucial issue for deciding whether to screen younger adults, however, is the incremental effectiveness of earlier treatment compared with delayed treatment for those patients with lipid disorders.

Ideally, we would like to have information from a randomized controlled trial that examined the effect of early screening and treatment (compared with delayed screening and treatment) on CHD events and mortality. Because such a study does not exist and is unlikely to be performed owing to the long follow-up period (30 years) that would be required, we must rely on indirect data to examine the arguments in favor of and against early screening and treatment.

Four main arguments can be offered for beginning screening and treatment earlier. First, earlier treatment with drugs and diet may prevent the development of atherosclerotic lesions that may increase the risk of future CHD events. Second, earlier identification of lipid disorders and treatment with diet therapy may be more effective because dietary patterns are easier to change at an earlier age. Third, knowledge of one's lipid disorder may make dietary therapy more effective. Fourth, early screening and treatment may reduce sudden death as the first presentation of CHD.

Four main arguments can be made against earlier universal screening. First, identification and treatment of lipid abnormalities at the later age thresholds (35 years in men and 45 years in women) may still allow enough time to prevent the majority of CHD events that would occur. Second, earlier treatment could expose many persons to years of unnecessary drug therapy, which may have unrecognized adverse effects. Third, a healthy diet low in saturated fat (eg, American Heart Association Step One) is now recommended universally. If the currently available evidence does not suggest that intensive individualized dietary advice is more effective in reducing future CHD events than general population advice to eat a low-fat diet (see Key Question No. 2), then early identification of persons with abnormal lipids is not warranted. Fourth, in light of the potentially small incremental benefit from screening and treating earlier, the marginal cost-effectiveness of early universal screening is low; the resources that would be devoted to screening and treating at earlier ages might be better spent on different health and nonhealth needs.

In the next section, we will examine and integrate the evidence for or against screening in young adults.

## Evidence about Screening Young Adults

### Atherosclerosis

Atherosclerotic plaques can be detected in autopsy studies of adolescents and young adults, ^190^ and these plaques are risk factors for CHD events. The exact strength of the relationship between atherosclerotic plaques and the incidence of future CHD events, including angina and acute MI, is not clear, because not all persons with these plaques will develop clinically evident CHD. Although the argument that early treatment would reduce these plaques and the possibility of future events is intuitively appealing. How much, if any, additional benefit is possible has not been established.

Knowledge of cholesterol levels. Data reviewed for Key Question No. 2 suggest that knowledge of one's cholesterol does not appear to increase the effectiveness of diet therapy overall, but may improve cholesterol reduction in those with initially high levels. The idea that early dietary change is more sustainable than changes made in later life has intuitive and logical appeal, although we were not able to identify any supporting evidence in our literature search.

The sustainability of such changes may also be facilitated by population changes in food fat content, school meals, and familial eating patterns. Such changes could make it more difficult for individualized therapy to show additional effectiveness.

### Sudden death

Another rationale that has been proposed to support screening for lipid disorders in young adults is that a large proportion of persons, including many with occult lipid disorders, will present with sudden death as the first and only manifestation of CHD. ^240^ This assertion is often coupled with a statement that 25% of CHD presents as sudden death, which is referenced to a 1985 paper by Kannel and Schatzkin. ^241^

The question that is germane to the issue of screening young adults, however, is the following: What proportion of CHD in young adults presents as sudden death, and how often does it occur? Further, what proportion of those in whom it does occur would not have been screened for lipid disorders (or even screened 5 years earlier) under a strategy of delayed screening? This group would include only those victims of early sudden death without previous evidence of CHD, a family history of CHD, or multiple other risk factors for CHD.

The Kannel and Schatzkin data show that for the entire Framingham cohort (including patients 35 to 84 years of age) sudden death accounts for 11.5% of all coronary events in men and 7.6% in women. ^241^ When angina is excluded as a presentation of CHD, sudden death accounts for 18.0% of CHD events in men and 24.3% in women; these data appear to be the basis for the 25% figure. However, the presence of angina should always prompt lipid screening, and in many cases we are here concerned with sudden death in young adults, so these data appear to be less useful for addressing the screening question than previously believed.

The relevant data show that for men 35 to 44 years, sudden death accounts for 8.1% of CHD presentations. Too few events occurred in women in that age range to measure the frequency of sudden death. For adults 45 to 54 years, sudden death accounts for 9.5% of events in men (although regular screening would have occurred 10 years earlier in the "delayed" screening strategy) and for 7.1% in women. The incidence of sudden death in men 45 to 54 years without known CHD was 2.4 per 1,000 persons and in women was so small as to be not measurable in Framingham. Even in women 55 to 64 years of age, the rate was only 1.2 per 1,000 women without CHD. These numbers probably would be even smaller if persons with other CHD risk factors (such as family history of CHD, diabetes, hypertension, or smoking) were excluded.

In summary, the incidence of CHD presenting as sudden death in adults 35 to 44 years of age is quite low, and it would be even lower if persons with multiple other CHD risk factors were excluded. In the absence of multiple CHD risk factors or a strong family history of early CHD, early screening to detect and treat hyperlipidemia will not prevent a large proportion of the few sudden deaths expected in young adults.

### Adverse effects and diet issues

To date, concerns about the long-term adverse effects associated with lipid-lowering statin drugs remain only theoretical. The drugs appear to have few short-term or medium-term adverse effects that would compromise quality of life or increase morbidity. Screening to improve the effectiveness of dieting therapy does not appear to be effective overall.

### Incremental benefit of earlier screening and treatment

The strategy of delayed screening is based on the arguments that the majority of the CHD events that would occur without treatment in a given cohort of persons can be prevented by screening and subsequent treatment at age 35 years in men and 45 years in women and that earlier identification and treatment adds little incremental benefit. This rationale is generally based on a systematic review and meta-analysis by Law et al. ^242^ Their work suggests that the majority (about 80%) of the potential benefit from lipid therapy, as predicted by cohort data, can be achieved after 5 to 10 years of treatment. By this argument, the preferred approach is to delay screening and treatment until about 5 to 10 years before the time that the absolute risk of events begins to rise to meaningful absolute levels. This approach will theoretically minimize potential adverse effects of long-term therapy and unnecessary drug costs without reducing benefit substantially. ^242^ Others have challenged this interpretation and its implications. ^237^

## Children and Adolescents

As with the discussion for young adults, little evidence supports the contention that the net benefits of screening and individualized treatment of children for lipid disorders are greater than the net benefits of simply providing general population advice to follow a healthy diet low in saturated fat after age 2 years and performing other recommended interventions to reduce future CHD risk. Compared with other population subgroups, children face more potential harms including labeling, the trauma of venipuncture, parental worry, and the costs associated with long-term therapy. Actual evidence about these outcomes is minimal, however.

### Special Populations

The evidence about cholesterol lowering in children, adolescents, women, and the elderly is previously discussed. Differences in the clinical approach to screening and treating African Americans do not appear to be large. Average cholesterol levels do not differ meaningfully between the 2 groups, and although trial data on African Americans are scarce, there is no good reason to believe that African Americans will respond differently than European American subjects at any given level of risk. Harms of drug therapy do not appear to be increased. ^243^ However, formulae to calculate CHD risk ^10^ ^,^ ^218^ have been developed mostly in patients of European descent and may not generalize well to African Americans. Few direct data exist about the prevalence of lipid disorders or evidence for the benefits of screening and treatment among Native American, Asian American, and Hispanic populations. Further research and wider recruitment in clinical trials would enable better estimates of the benefits of screening and treatment in persons of non-European descent.

## Final Conclusions - Whom To Screen

Table 10 summarizes the evidence on the question of whom to screen and indicates our evaluation of the overall quality of that evidence. The explanation of these grades can be found in Appendix 2.

The evidence is good that treating lipid disorders in middle-aged men of European descent reduces CHD events, CHD mortality, and perhaps total mortality in patients with sufficient CHD risk. Screening and treatment in middle-aged women and the elderly with sufficient CHD risk may also be effective, although the effect on total mortality for women is unclear. The balance of benefits and harms from screening and treating young adults or children is not clear from the available evidence , but screening to implement more aggressive dietary therapy does not appear to produce large improvements in CHD risk profiles above and beyond the improvements from general population advice to follow a healthy diet.

### Final Conclusions - Frequency of Screening

No direct data inform the question of appropriate frequency of screening. Chiefly for that reason, previous recommendations of the US Preventive Services Task Force (USPSTF) did not state a preferred interval. ^12^ ^,^ ^21^ By contrast, the recommendations of the National Cholesterol Education Program suggested a 5-year interval for persons with previous normal results and more frequent screening for those who have borderline values. ^3^

Several factors enter into a decision about screening frequency. These include the usual rates of change in cholesterol levels over time, the variability of individual cholesterol measurements, the likelihood of finding a result that would lead to a change in management, and the feasibility and costs of different frequencies of screening. A universal 5-year interval, for example, is simple to implement, but it may impose more frequent screening than is necessary on patients with few or no other risk factors and low-risk values on previous screening measurements. Using a more variable algorithm in which patients' frequency of screening would be related to their previous results could be more efficient in diagnosis, but this approach may be confusing or difficult to implement. Again, computer reminders and decision support tools are promising -- but not fully tested -- means of increasing feasibility and accuracy.

## Future Research Needs

As noted throughout the report, several important issues related to screening for lipid disorders have not been well studied. Foremost, the efficacy of lipid therapy in men of non-European descent and in all women, the elderly, and younger persons with multiple risk factors or diabetes should be examined more rigorously. The effectiveness of novel methods of diet therapy, including " Mediterranean" diets, should be examined in primary prevention populations. Further data on the real-world use of lipid screening and means of improving the accuracy and efficiency of different screening strategies are warranted as well. Better information about the effect of treating isolated abnormal triglycerides will help define the role of screening with triglyceride measurement, as will further research on the role of novel risk factors such as homocysteine or C-reactive protein. Finally, analysis of the optimal sequencing and combinations of different efforts to decrease CHD events (aspirin, treatment of hypertension, smoking cessation therapy) ^211^ would help better clarify the timing and role of lipid-lowering therapy.