# Results

In this chapter, we present the results of our systematic evidence review (SER). The results are organized according to the Key Questions defined in our analytic framework (Chapter 1., Figure 1). The Key Questions that constitute the major headings of this chapter correspond to the major linkages of the analytic framework. We first address the questions of whether either drug therapy or diet therapy is effective in reducing the morbidity and mortality from coronary heart disease (CHD) (ie, Key Question Nos. 1 and 2). We then examine different strategies for identifying patients with lipid disorders who are amenable to treatment efforts to reduce their risk for CHD events (Key Question No. 3).

## Key Question No. 1: Drug Therapy for Lipid Disorders

We identified 4 trials of drug therapy for lipid disorders in the primary prevention of CHD (see Appendix 3, Evidence Table 1). These include 2 older (pre-1995) trials: 1 using the bile-acid binding resin cholestyramine (Lipid Research Clinical trial [LRC]) ^96^ and 1 (Helsinki Heart Study [HHS]) using the fibric acid derivative gemfibrozil. ^97^ The other 2 trials were published either during or after 1995 and used HMG co-A reductase inhibitors or "statin" drugs: the West of Scotland Coronary Prevention Study (WOSCOPS) used pravastatin, ^98^ and the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS-TexCAPS, hereafter TexCAPS) used lovastatin. ^99^

We identified 4 additional trials that could not be definitively included or excluded based on our eligibility criteria. The first, an older trial of clofibrate, was not included because clofibrate is not regularly used in the United States to treat patients with lipid disorders owing to concerns about its safety. ^41^ The 3 other articles used ultrasound measurements of carotid or femoral artery atherosclerosis to determine eligibility and as main outcomes. ^100^ ^-^ ^102^

We excluded several other studies that included mixed populations of subjects with and without previously diagnosed CHD because the results for the 2 groups could not be distinguished from one another. (See Appendix 1, Table 1-1 for more details.)

### Effects of Drug Therapy in Adults

#### CHD Events

##### Trial results

As documented in Evidence Table 1 (Appendix 3), the 4 included trials were conducted mainly among middle-aged men of European descent. The LRC, HHS, and WOSCOPS trials enrolled patients with elevated levels of total cholesterol (TC) and low-density lipoprotein (LDL) cholesterol, whereas the TexCAPS study included men and women with TC levels close to the United States average and low levels of high-density lipoprotein (HDL) cholesterol. The trials ranged from 5 to 7 years in duration, and all examined the effect of drug therapy on the incidence of CHD events, including CHD mortality, using a placebo-controlled, double-blind methodology. In each trial, the intervention and control groups both received low-intensity dietary interventions. Few diabetics were enrolled in any of the 4 trials.

The 2 trials employing statin drugs (WOSCOPS and TexCAPS) had larger initial decreases in TC (20% and 18%) than the LRC or HHS (8.5% and 11% ) (Table 4). The relative risk reductions for CHD events were larger in the statin trials, supporting the observation that reduction in events appears proportional to the magnitude of reduction in TC. The relative risk reductions for CHD events ranged from 19% to 37%. Relative risk reductions for CHD mortality ranged from 20% to 28%. None of the trials was designed with sufficient power to address the question of whether drug therapy reduces total mortality in primary prevention settings.

Table 4: Main Results from Trials of Drug Therapy

Trial /Year | Drug /Dose | Percent Change in TC | RRR CHD Events (95% CI) | ARR CHD Events (5 years)
LRC, 1984 ^96^ | Cholestyramine 24g qd* | 8.5 | 19% (3-32%) | 1.1%
HHS, 1987 ^97^ | Gemfibrozil 600 mg bid** | 11 | 34% (8-53%) | 1.4%
WOSCOPS, 1995 ^98^ | Pravastatin 40 mg qd | 20 *** | 31%§ (17-43%) | 2.4%
TexCAPS, 1998 ^99^ | Lovastatin 20-40 mg qd | 18 | 37% (21-50%) | 1.25%§§

NOTE: LRC = Lipid Research Clinics; HHS = Helsinki Heart Study;TexCAPS = Texas Coronary Atherosclerosis Prevention Study; WOSCOPS = West of Scotland Coronary Prevention Study.

* qd indicates once daily

** bid indicates twice daily

*** Percentage based on actual use, not intention to treat.

§ The RRR when unstable angina is excluded is 43%.

§§ Percentage absolute risk reduction for nonfatal MI and CHD deaths only.

The results of the 2 new trials (WOSCOPS and TexCAPS) have potentially important implications for screening and therapy. We describe them in increased detail here to determine the degree to which they can be generalized to the population at large.

WOSCOPS randomized 6,600 middle-aged men (ages 45 to 64 years) with LDL cholesterol between 155 and 232 mg/dL (4-6 mmol/L) to either pravastatin 40 mg each day or placebo. Approximately 81,000 men were screened over 3 visits to identify 6,595 who met the entry criteria and agreed to participate. The randomized patients were similar to the initial 81,000-man cohort with respect to age, blood pressure, smoking status, and alcohol consumption. Mean body mass index was slightly higher in the randomized patients (26.1 versus 25.8), and the screened patients were more likely to have had a history of angina or previous myocardial infarction (MI) (11.6% versus 4.6%). The trial participants had the following CHD risk factors: 39% were smokers, 1.2% were diabetic, 5.7% had a family history of early CHD, and 11% were currently taking medication for hypertension. Few participants were taking aspirin (2.9%) or beta blockers (7.2%). ^103^ Unlike the other studies, patients with angina but no previous MI who had not been symptomatic or hospitalized within the past year were not excluded and accounted for 5% of the study group. Treatment with pravastatin was associated with reductions in CHD events (relative risk reduction [RRR], 31%; absolute risk reduction [ARR], 2.4%), in CHD mortality (RRR, 30%; ARR, 0.7%), and in total mortality (RRR, 22%; ARR, 0.9%.)

In the TexCAPS trial, 102,000 men and women were screened at 2 sites in Texas to identify potential participants in the trial. Potential participants underwent 4 pre-randomization visits over 14 weeks that included dietary advice using the American Heart Association Step One diet and also had to complete a 2-week placebo run-in period. Compliant, eligible subjects were then randomized to either lovastatin titrated to 20 to 40 mg per day or placebo. ^104^ The approximately 6,600 randomized subjects had a mean age of 58 years, 85% were men, and 89% self-reported their race as white. Few subjects were diabetic (2.5%), and only 17% were taking aspirin. Nearly 16% had a family history of early CHD, and 22% were hypertensive. Only 12.5% were current smokers. ^99^ No data are available to compare them with the cohort that had been screened for inclusion. Treatment with lovastatin reduced CHD events (RRR, 43%; ARR, 1.25%) but had no effect on CHD or total mortality.

Overall, the 4 included trials scored highly on our measures of aggregate internal validity, based on the strength of randomization, adequate concealment, intention-to-treat analysis, and the absence of differential dropouts or losses to follow-up. Their external validity was fair in the aggregate, based on the facts that they did not enroll sufficient women or persons of non-European descent and that 2 were conducted in Europe.

#### Meta-analysis

We performed meta-analyses to estimate better the effect of drug therapy on CHD events, CHD mortality, and total mortality. The full methods and results are reported in a separate publication. ^95^ The main results of the meta-analyses, reported as summary odds ratios (OR) with 95% confidence intervals (CI), are shown in Figures 2A-C, 3A-C, and 4A-C. We present the results here using a fixed effects model.

The combined results of the 4 main trials (Figures 2A-C) suggest that drug therapy decreases the relative risk of total CHD events (defined as the sum of nonfatal MI and deaths from CHD) by 30%. Drug therapy also reduces the relative risk of CHD death by 26%, with a 95% CI from 2% to 43%. Drug therapy appears to have little overall effect on total mortality for the 5 to 7 years over which these trials were conducted (OR, 0.91; 95% CI, 0.78, 1.07). However, the overall result may mask total mortality benefit in higher-risk patients. The WOSCOPS trial, which enrolled the patient population at highest risk (as measured by the event rate in the placebo arm), found a 22% relative reduction in total mortality with a borderline statistical significance. The absolute risk reduction, however, was modest (0.9% over 5 years). The other 3 trials clustered around the estimate of no effect for total mortality.

Figure 2A: Effect of Treatment on Total CHD Events

Figure 2B: Effect of Treatment on Total CHD Mortality

Figure 2C: Effect of Treatment on Total Mortality

Figure 3A: Effect of Treatment on Total CHD Events

Figure 3B: Effect of Treatment on Total CHD Mortality

Figure 3C: Effect of Treatment on Total Mortality

Figure 4A: Effect of Treatment on Total CHD Events

Figure 4B: Effect of Treatment on Total CHD Mortality

Figure 4C: Effect of Treatment on Total Mortality

Hebert et al performed a meta-analysis of primary prevention trials of statin therapy before the completion of the TexCAPS trial. ^105^ They included WOSCOPS and 2 trials that had been designed to examine the effect of statin therapy on the size of ultrasound-measured atherosclerotic plaques in the femoral or carotid arteries; in 1 of these 2 trials, 10% of patients had a previous history of MI and thus were not included in our sample. ^102^ They found a 37% reduction in CHD mortality (OR, 0.63; 95% CI, 0.45, 0.89) and a significant 26% reduction in total mortality (OR, 0.74; 95% CI, 0.58, 0.95).

We recalculated the results of our meta-analysis to clarify 2 points: the effect of including the 4 articles that could not be definitively included or excluded and the effect of the statin drugs when considered alone. ^41^ ^,^ ^101^ ^,^ ^102^ ^,^ ^106^ Including the 4 additional studies (Figures 3A-C) did not have a large impact on the summary effect size for total CHD events (new summary OR, 0.79; 95% CI, 0.63, 1.00). This step did attenuate slightly the effect on CHD mortality (new summary OR, 0.79; 95% CI, 0.63, 1.00) but did not affect total mortality.

The statin drugs reduce cholesterol to a greater degree than older drugs. We performed another meta-analysis to determine if the effect of the statins on CHD events, CHD mortality, and total mortality was greater when they were considered alone (Figures 4A-C). For the statin trials alone, the net reduction in the odds of CHD events compared with placebo was slightly larger (35%) than for all drugs (30%), as was the reduction in CHD mortality (31% versus 26%). No significant effect on total mortality was found when the statin trials were considered alone.

These data, when combined with the findings from secondary prevention trials and systematic reviews, provide strong evidence that drug therapy reduces CHD events and CHD mortality. Further, the magnitude of that benefit appears to be closely related to the underlying risk of CHD in the population undergoing treatment.

#### Conclusions - CHD Events

The question of whether lipid therapy reduces total mortality in primary prevention settings remains unclear. The existing trials do not have sufficient power, even when meta-analyzed, to confirm or exclude potentially meaningful effects, at least in part because the CHD and total mortality rates over the 5- to 7-year-long trials are low. Total mortality might be reduced for higher-risk patients (such as those in WOSCOPS) or if follow-up were continued for several more years. Improvements in secondary prevention and post-MI care, however, may increase the survival of those who are not treated before CHD becomes known and thus decrease some of the potential benefit of early therapy. A final important consideration is that most of the participants in the trials examined here were not taking aspirin. If aspirin reduces MI risk, then the CHD event and mortality rates would be even lower and the absolute benefits of lipid therapy smaller.

#### Strokes

Hebert et al also determined the effect of HMG co-A reductase inhibitor drugs on stroke outcomes. ^107^ They combined data from 14 trials of primary and secondary prevention of CHD and found that, overall, subjects assigned to statin drugs had a 29% relative risk reduction for all strokes (95% CI, 14%, 41%). When they considered 3 primary prevention studies alone (including 2 studies measuring plaque regression as their primary outcomes, but not including the TexCAPS study, which had not yet been published), they found the odds ratio for the incidence of stroke to be 0.80 (95% CI, 0.54, 1.16), which is not statistically significant. Another meta-analysis of statin trials (also pre-TexCAPS) by Warshafsky et al found a similar result for total strokes in primary prevention trials: OR, 0.85; (95% CI, 0.57, 1.28). ^108^

For the primary prevention studies, the average incidence of stroke in the control group was 1.5 % for trials lasting 3 to 5 years. Thus, statin drugs appear to reduce stroke in secondary prevention settings but may not have been proven to do so in primary prevention settings. If statin therapy reduces stroke, the absolute benefit will be smaller than that for CHD events.

### Effects of Drug Therapy in Children and Adolescents

We identified no trials examining the impact of drug therapy for children and adolescents that measured actual clinical endpoints such as CHD events because these events are extremely rare at young ages. Several studies have examined short- to medium-term drug treatment for children and adolescents with familial lipid disorders, but they have been too short (8 weeks to 1 year) and too small to draw definitive conclusions about harms or benefits. ^109^ ^-^ ^112^

#### Harms and Adverse Effects

For cholesterol-lowering drug therapy to be effective in the primary prevention of CHD, the drugs must be free from serious and frequent adverse effects because the absolute benefit of treatment is lower in the primary prevention population than in secondary prevention groups. The literature on the adverse effects of lowering cholesterol is vast, and a full review is beyond the scope of this SER.

This section highlights the most important and relevant evidence regarding adverse effects of lipid-lowering drugs and how such effects influence the decision to screen patients in primary care settings and treat those who are found to have lipid disorders. We focus on the statin drugs because they are the most commonly prescribed lipid-lowering agents (accounting for 90% of prescriptions written for cholesterol-lowering drugs in the United States in 1998) ^113^ and because the evidence for their benefits is also the strongest.

To examine adverse effects, we searched the literature broadly to identify all types of studies, including case series, observational data, and randomized trials. Although randomized trials are most likely to control for bias, they may have insufficient power to detect rare events. Further, they use selected, healthy patient populations and employ frequent monitoring, so their results may not be generalizable to real-world practice.

Numerous observational studies have noted the association between very low serum cholesterol levels (levels lower than usually achieved with single drug therapy) and adverse outcomes, including mortality. Much of the association, however, appears to be attributable to underlying disease processes that produce low cholesterol levels and adverse outcomes, not to the low levels themselves. ^114^ The risk of hemorrhagic stroke, however, does appear to be increased with low serum cholesterol in observational studies and perhaps in meta-analysis of secondary prevention trials. ^108^ ^,^ ^115^ Although the relative risk of hemorrhagic stroke is relatively large (RR, 1.86; 95% CI, 1.37, 2.53) for the subgroup with TC below 5 mmol/L (190 mg/dL), the absolute risk is quite small and is canceled out by the more common reductions in CHD and ischemic stroke. ^108^

Any adverse effects on CHD outcomes are subsumed within the main outcome variables (CHD mortality, total CHD events) from large studies. Because CHD events are common and appear to be decreased by the main effect of lowering lipid levels, any small adverse effect on CHD outcomes due to another mechanism will produce only an attenuation of the net benefit of treatment.

Numerous studies have examined putative non-CHD adverse effects (see Tables 5 and 6). ^15^ ^,^ ^16^ ^,^ ^98^ ^,^ ^99^ ^,^ ^116^ ^-^ ^137^ The non-CHD adverse events can be divided into 2 groups: (1) short- to medium-term effects of therapy (initiation to 5 years of therapy); and (2) long-term effects (greater than 5 years of therapy). The remainder of this section considers these topics in turn.

##### Short- to Medium-term Adverse Effects for Statin Drugs

Several potential short- to medium-term adverse events have been well studied in large randomized controlled trials (RCTs) of sufficient duration and size to have adequate power to identify even small differences in their occurrence (Table 5). Commonly considered adverse effects include the following: (1) creatinine kinase (CK) elevations and myopathy, (2) liver enzyme elevations and hepatic dysfunction, (3) lens opacities and cataracts, and (4) cancer.

Table 5. Frequency of Important Adverse Effects From Large Trials of HMG Co-A Reductase Inhibitors (Statin Drugs)

Study | Adverse Event | Cumulative Incidence Intervention/Control
Scandinavian Simvastatin
Survival Study (4S) ^116^ | Elevated CK (>10 x nml) | 0.3% / 0.05%
| Myalgias | 3.7% / 3.2%
| Elevated AST (>3 x nml) | 1.0% / 1.1%
| Elevated ALT (>3 x nml) | 2.2% / 1.6%
| Depression | 2.2% / 2.5%
| Cancer * | 4.0% / 4.3%
CARE ^16^
| Elevated CK (>10 x nml) | 0.6% / 0.3%
| Elevated liver enzymes (AST or ALT) | 3.2% / 3.5%
| Cancer* | 8.3% / 7.7%
WOSCOPS ^98^
| Elevated CK (>10 x nml) | 0.09% / 0.03%
| Myalgias / muscle aches | 3.5% / 3.7%
| Elevated ALT (>3 x nml) | 0.48% / 0.36%
| Cancer* | 3.5% / 3.2%
TexCAPS ^99^
| Elevated CK (>10 x nml) | 0.6% / 0.6%
| Elevated AST or ALT (>3 x nml) | 0.6% / 0.3%
| Cancer* | 7.6% / 7.8%
LIPID ^15^
| Elevated CK (>10 x nml) | No difference
| Elevated ALT (>3 x nml) | 2.1% / 1.9%
| Serious hepatic disease | No difference
| Cancer* | 8.9% / 9.3%

NOTE: ALT = alanine amino transferase; AST = aspartate aminotransferase; CK = creatinine kinase; nml = normal;

CARE = Cholesterol and Recurrent Events Study; LIPID = Long-Term Intervention with Pravastatin in Ischemic Disease;

TexCAPS = Texas Coronary Atherosclerosis Prevention Study; WOSCOPS = West of Scotland Coronary Prevention Study.

*Incidence of new primary cancers (excluding nonmelanoma skin cancers).

###### Elevation in CK and myopathy

Overall, myopathy related to the use of statin drugs(including muscle soreness (myalgias), weakness, or CK elevations(may occur in about 1 of 1,000 users. Patients taking higher doses, concurrently using other lipid-lowering medications (particularly gemfibrozil or niacin) or inhibitors of P-450 enzyme systems, or having complicated underlying medical problems appear to be at higher risk. ^118^ Cases of polymyositis- and dermatomyositis-like syndromes and of rhabdomyolysis and renal failure have been reported, but their frequency appears to be uncommon since they have not been found commonly in randomized trials. ^119^ ^,^ ^121^ ^,^ ^123^ ^-^ ^125^

The large RCTs of statins also have not found significant differences in the rates of either CK elevations greater than 10 times normal levels or myopathic symptoms (Table 6). ^13^ ^,^ ^15^ ^,^ ^16^ ^,^ ^98^

Table 6. Adverse Effects of HMG Co-A Reductase Inhibitors (Statin Drugs), by Type of Harm

Source | Study Design | Findings
Myopathy, Elevated Creatinine Kinase, Rhabdomyolysis, and/or Renal Failure
Pierce et al, 1990 ^118^ | Case series (FDA) | 12 case reports of elevated CK levels for patients taking lovastatin and gemfibrozil concurrently; 5 patients had associated, reversible ARF
Wallace and Mueller, 1992 ^119^ | Case report | Rhabdomyolysis and ARF in patient who had been taking lovastatin for 14 months
Contermans et al, 1995 ^120^ | RCT (24 subjects) | No difference between patients on simvastatin or pravastatin in exercise-induced CK release or muscle histology
Hill et al, 1995 ^121^ | Letter/Case report | Dermatomyositis developing in a 76 yo woman taking simvastatin x 18 months - patient died of respiratory failure
Scalvini et al, 1995 ^122^ | Case report | Myopathy and inflammatory changes on muscle biopsy in patient taking pravastatin x 5 months
Chu et al, 1997 ^123^ | Case report | Rhabdomyolysis, renal failure requiring dialysis for 3 weeks after 4 weeks of lovastatin monotherapy
Giordano et al, 1997 ^124^ | Case report | 42 yo with elevated CK and polymyositis developing 3 months after starting simvastatin
Wicher-Muniak et al, 1997 ^125^ | Case report | Elevated CK, muscle pain and weakness 2 months after starting simvastatin. Resolved off drug
Elevation of Liver Enzymes
Hartleb et al, 1999 ^126^ | Case report | 57 yo man (taking 20 mg pravastatin/day x 2 months) found to have intrahepatic nonobstructive jaundice on biopsy; resolved off drug
Lens Opacities and Cataracts
Laties et al, 1991 ^127^ | RCT | No difference in lens opacities between lovastatin and placebo at 48 weeks (8245 patients enrolled)
Harris et al, 1995 ^128^ | RCT | No evidence of differences in lens opacity between simvastatin and placebo at 18 months (621 patients)
Cancer
Newman and Hulley, 1996 ^129^ | Animal studies | Statin drugs and fibric acid derivatives have caused tumors (malignant and benign) in laboratory animals
Depression or Decreased Cognition
Boumendil and Tubert-Bitter, 1995 ^130^ | Cohort study | Diet (PR = 1.83) and simvastatin (PR=2.18) associated with increased work absenteeism from depression
Cutler et al, 1995 ^131^ | Cross-over trial | No differences in cognitive measures after 4 weeks among those taking simvastatin or pravastatin compared with controls
Davidson et al, 1996 ^132^ | Before/after uncontrolled trial | Increased scores on CES-D scale screener after 6 weeks of therapy; 2 patients met criteria for depressed mood
Delva et al, 1996 ^133^ | Nonrandomized experiment | Beck depression mean score lower (worse) in patients treated for high cholesterol (5.4) than in healthy controls (age and sex matched) (2.3)
Golomb 1998 ^134^ | Systematic review | Several lines of evidence, including cohort data, animal studies, and some meta-analyses, support the link between low cholesterol and violence. Large RCTs have not found increased risk
Lupus-like Reaction
Sridhar and Abdulla, 1998 ^135^ | Case report | Case of woman who developed lupus reaction and ARDS (and later died) 1 week after starting fluvastatin
Peripheral Neuropathy
Jeppesen et al, 1999 ^117^ | Case reports | 7 cases of peripheral neuropathy in patients where other potential causes had been excluded
Teratogenesis
Manson et al, 1996 ^136^ | Descriptive study | Rates of adverse pregnancy outcomes were not increased over expected in data from inadvertent exposures to lovastatin or simvastatin
Testicular Function
Azzarito et al, 1996 ^137^ | Before/after trial | 8 patients had no changes in testicular function over 12 months of treatment with simvastatin

NOTE: ARDS = Acute Respiratory Distress Syndrome; ARF = acute renal failure; CES-D = Center for Epidemiological Studies-Depression; CK = creatinine kinase; PR = prevalence ratio; RCT = randomized controlled trial; yo = year old.

###### Liver enzyme elevation

Statin drugs have been reported to cause dose-dependent, asymptomatic liver enzyme elevations in about 1% of patients. Most of these elevations occur in the first year of therapy. ^32^ Cases of the development of frank cholestatic hepatitis that resolve with the discontinuation of therapy have been reported. ^126^ Data from the large RCTs using low to moderate medication doses do not, however, show a clear pattern of such elevations with active treatment, as the rates of elevated liver enzymes are similar in intervention and control groups.

###### Lens opacities

Data from 2 large RCTs in which careful ophthalmologic examinations were performed found no increase in the frequency of cataracts or other visual changes. ^127^ ^,^ ^128^

###### Cancer

To date, large trials (Table 6) and recent meta-analyses ^105^ have not found increases in the frequency of cancers among those assigned to the active drug as compared to those taking placebo. These trials have an average duration of 5 years, so further surveillance is required to exclude long-term effects.

Concern was raised in the CARE study that the frequency of breast cancer was increased among women who receive active drug in their arm. ^16^ Further trial data from primary and secondary prevention trials have not confirmed this finding. ^138^

###### Violence

Golomb reviewed several lines of evidence, including observational studies, older trials, and animal data, supporting the link between lower cholesterol and violence, ^134^ but recent large trials of the statin drugs have not shown excess violence-related morbidity and mortality among those assigned to cholesterol-lowering therapy with statin drugs.

###### Depression

Some small experimental studies have suggested that lowering cholesterol with drug therapy may increase scores on indices of depressed mood, ^132^ ^,^ ^133^ but others have not found any differences in mood or cognitive abilities. ^131^ One large cohort study found an increased prevalence of depression-related work absences among those taking simvastatin or following a low-fat diet, but the investigators did not control for confounding by comorbid conditions such as hypothyroidism or CHD. ^139^ Depression does not appear to be more common in the large randomized trials of drug therapy. ^115^

###### Other potential adverse effects

Jeppesen et al reported 7 cases of peripheral neuropathy among patients taking statins with no other plausible explanations for their neuropathic symptoms. ^117^ Further evidence, however, will be required to determine if these neuropathies can be attributed to the statins. Manson et al found that adverse pregnancy outcomes were not greater than expected among women inadvertently exposed to statins during pregnancy. ^136^ Finally, Azzarito et al performed a before and after trial that showed no effect on testicular function in patients taking simvastatin for 1 year. ^137^

##### Long-term Adverse Effects of Statin Therapy

Statin drugs have been extensively studied in the past decade, and they appear to be relatively safe with respect to serious short- and medium-term outcomes, as described above. We do not yet know, however, if they will have serious long-term adverse effects, as they have not been in use for a sufficient amount of time to allow such effects to arise. The announcement of a collaboration among the investigators of the large trials of drug therapy to combine and pool data to gain better sensitivity for detecting rare adverse effects is encouraging. ^140^

##### Harms and Adverse Effects of Non-Statin Drugs for Lipid Disorders

###### Gemfibrozil

Gemfibrozil, a fibric acid derivative, has been reported to cause gastrointestinal (GI) disturbance (abdominal pain, nausea) in 5% of users, ^141^ and it may increase the likelihood of gallstones. When used with lovastatin or cirvistatin, it increases the risk of myopathy and rhabdomyolysis. ^118^ In the HHS, new dyspepsia or abdominal pain was reported by 20% of men taking gemfibrozil and 15% of controls. Cholecystectomies and appendectomies were more likely in intervention subjects. After 8.5 years of follow-up, total mortality was slightly higher in the gemfibrozil group than in the placebo group, but the results did not reach statistical significance (4.9% versus 4.1%, P = 0.12). ^142^ In the Veterans Administration High-Density Lipoprotein Cholesterol Intervention Trial (HIT), patients taking gemfibrozil 1,200 mg per day were more likely than controls to report dyspepsia (40% and 34%, respectively). Rates of biliary disease did not differ between groups, and total mortality was slightly lower in the treated group. ^18^

###### Niacin

The most problematic adverse effect of niacin is dose-related flushing, which has limited long-term adherence. ^139^ GI symptoms (nausea, vomiting, abdominal pain) are also commonly reported, but the most worrisome adverse effect is hepatic toxicity: up to one third of patients may develop abnormal liver function tests, and fulminant hepatic failure has resulted from use, particularly with the extended-release version. ^143^ Exacerbations of diabetes and gout are also common. ^139^ ^,^ ^144^

###### Bile-acid binding resins

The bile-acid binding resins seem to increase GI symptoms, including bloating and nausea, and they can affect the absorption of other drugs. Otherwise, they appear to be relatively safe and have been studied for a longer period of time than statins. ^3^

##### Summary of Harms and Adverse Effects of Drug Therapy

Based on data from multiple clinical trials, statins appear to have few important adverse effects over the short- or medium-term (initiation to 5 years), but their long-term safety is currently unknown. Other agents, including gemfibrozil, niacin, and bile-acid binding resins, appear to have either more frequent, minor adverse effects or rare major adverse effects. The safety experience for bile-acid binding resins and niacin, however, is based on a longer period of time than is the case for the statin drugs.

### Adherence to Lipid-lowering Therapy

The magnitude of the "real world" effectiveness of drug therapy for lipid disorders is related to the level of adherence to such therapy. The rates of adherence found in randomized trials of lipid-lowering drug therapy may not be generalizable to real-world settings where follow-up and monitoring are less rigorous, patients have not been preselected as being willing and able to follow protocols, and the medications are not provided free of charge. If adherence rates in ordinary practice settings are lower than those found in trials, then the potential absolute benefit of therapy may be attenuated.

In the WOSCOPS study, 15% of subjects had withdrawn after 1 year and 30% of subjects after 5 years. The rates of withdrawal were equal between intervention and placebo groups, and it is not clear what proportion left because of nonadherence or because their regular providers discontinued study medications because of potential adverse effects or a perceived lack of efficacy. ^98^ In TexCAPS, the investigators reported that 99% of participants took greater than 75% of their pills as determined by pill counts; 71% of subjects receiving lovastatin and 63% of subjects receiving placebo maintained adherence until the end of the trial. ^99^ Previous trials of statin drugs had shown rates of discontinuation of 16% at 1 year in a mixed primary and secondary trial ^35^ and 6% to 12% at 4 to 5 years in 3 large secondary prevention trials. ^13^ ^,^ ^15^ ^,^ ^16^

The study populations from the large trials may be systematically different from the target populations for screening with respect to the likelihood of adherence. Data from real-world settings may have higher generalizability. Andrade and colleagues examined the rate of treatment discontinuation of lovastatin in a population enrolled in a health maintenance organization from 1988 to 1990 and found a 1-year rate of 15% and a 2-year rate of 25% to 30%. ^145^ About 50% of discontinuations were attributed to adverse effects. Avorn and colleagues examined the same question among patients older than 65 years of age, using 1990 to 1991 data from the New Jersey and Quebec drug assistance pharmacy programs. ^146^ Lovastatin users had the highest rate (64%) of "persistent" use. Patients with known CHD or multiple risk factors were more likely to continue their drug therapy than patients without those characteristics.

Although the Andrade et al and Avorn et al data are drawn from appropriate study populations, they are somewhat dated. ^145^ ^,^ ^146^ Better evidence reflecting current real-world practice and available therapies would be helpful in clarifying the actual extent of adherence to drug therapy and its relationship to the populations' expected net benefit from treatment.

### Summary

Drug therapy for lipid disorders reduces the relative risk for CHD events and for CHD mortality by approximately 30%. Statin drugs have produced larger reductions in cholesterol and appear to reduce events more than the older drugs. The absolute risk reduction with drug therapy depends on the underlying risk in the person or population being treated. Total mortality is not reduced after 5 to 7 years of treatment in lower-risk patients (risk of CHD events less than 1.5% per year), but it may be reduced in higher-risk populations or with longer follow-up. Short- to medium-term adverse effects appear uncommon with statins, but long-term effects are unknown. Women, elderly persons (up to age 70), and persons of non-European descent appear to have similar relative risk reductions with drug treatment, although they have been studied less than middle-aged men.

## Key Question No. 2: Diet and Exercise Therapy for Lipid Disorders

We examined the following 4 subsidiary questions for the linkage (Key Question No. 2) of the effect of diet and exercise therapy on patients with lipid disorders.

1. What is the effect of dietary counseling in primary care settings on cholesterol levels?

2. What is the effect of dietary counseling on CHD events?

Does knowledge of one's cholesterol level increase the effectiveness of dietary therapy for lipid disorders?

What is the effect of exercise advice on cholesterol levels and CHD events?

In this review, we consider dietary therapy to be general dietary counseling for free-living patients without known CHD conducted by a health care provider (physician, nurse, dietitian) individually or in a group format. This report does not attempt to measure the effect of population-level interventions such as television public service announcements or changes in legislation. It is specifically focused on the effects of diet therapy on lipid levels and the risk of CHD events or mortality. The evidence for general counseling to promote a healthy diet and its effect on other health endpoints will be considered in a separate report from the USPSTF; population-level interventions are addressed by the Centers for Disease Control and Prevention's Task Force on Community Preventive Services. The effect of dietary supplements is also not considered here.

The relationships among diet, cholesterol, and heart disease have been demonstrated in numerous ecologic and observational studies. In international comparisons, rates of CHD are associated with national dietary patterns, especially saturated fat intake. In the United States, broad changes over the past 30 years in dietary patterns, particularly the consumption of saturated fat, have been accompanied by reductions in the population's average TC levels. ^7^ These changes are believed to be one of a number of factors that have contributed to recent declines in mortality from CHD.

In addition, individualized dietary interventions (most, but not all, of which lower TC) have been shown to reduce CHD events in specific settings. A review for the Cochrane Collaboration examined 27 RCTs that employed reduced or modified fat diets for at least 6 months and that also collected data on mortality or cardiovascular morbidity (trials including interventions aimed at other risk factors such as smoking were not included). ^147^ Eight trials accounted for 99% of all cardiovascular events observed: 6 enrolled outpatients with preexisting heart disease and the remaining 2 studied institutionalized patients. Of the interventions employed, 3 trials used dietary education and counseling, 3 provided counseling plus supplements of polyunsaturated fat or fatty fish, and 2 employed institutional diets high in polyunsaturated fat. The pooled analysis showed an average reduction in total cholesterol of 11%, a statistically significant reduction in cardiovascular events (RR = 0.84; 95% CI 0.72 to 0.99), and a trend to lower cardiovascular mortality (RR = 0.91; 95% CI 0.77 to 1.07). Trials of longer duration (2 years or more) demonstrated greater effects than shorter trials.

Although these findings support the cardiovascular benefits of lowering cholesterol through specific dietary interventions, they are not easily generalized to the impact of typical outpatient diet advice provided to patients with high cholesterol. For individual dietary advice to be effective, it must produce long-term, clinically significant improvements in lipids and coronary risk beyond those that would occur as a result of secular changes and other community-based interventions aimed at the general population. Further, the dietary advice must be able to be replicated in real-world settings. In the following sections, we will examine the effects of dietary counseling in several settings relevant to primary care practice.

### Effectiveness of Dietary Advice in Primary Care Settings

#### Trials

Evidence Table 2 (Appendix 3) examines the 6 RCTs of dietary counseling provided in primary care settings with at least 12 months of follow-up. ^144^ ^,^ ^148^ ^-^ ^153^ In general, the studies were well designed and well conducted, and they had high internal validity. Their external validity was compromised only by the fact that they were all done in Europe, making their external validity fair for United States populations.

Overall, the net reductions in TC were small, with magnitudes of 2% to 3.7%. No studies in primary care settings examined the effect of dietary counseling on actual CHD events. The British Family Heart Study, a multimodal intervention designed to improve several risk factors, including serum cholesterol, examined the change in a cardiovascular risk score. In that trial, intervention subjects reduced their relative risk of CHD by 16% at 1 year, of which a 4% reduction could be attributed to changes in serum cholesterol. ^153^ In most cases, cholesterol reduction was largest for those with the highest initial levels.

In the Swedish Cost Effectiveness of Lipid Lowering study (CELL), Lindholm et al examined the effect of different combinations of drug and diet therapy on cholesterol levels and cardiovascular risk over 18 months. ^152^ Patients 30 to 59 years of age with hyperlipidemia (TC > 250 mg/dL) and at least 2 other CHD risk factors were randomized in a factorial design to usual or intensive dietary advice with or without concurrent drug therapy with pravastatin. Outcomes of interest were net changes in lipid levels, CHD risk (using a Framingham risk score), and cost-effectiveness.

Usual dietary advice consisted of brief advice from providers to reduce fat, lose weight, take exercise, and stop smoking. These messages were reinforced with a brief pamphlet. Intensive advice consisted of 6 group sessions (45 minutes each and 1 full-day meeting) with specific advice about dietary changes. Adherence over the course of the trial was high, and dropout rates were low.

Usual dietary advice alone produced no change in cholesterol levels after 18 months. Intensive advice, compared to usual advice, produced a net reduction of TC of 2.2%. The TC/HDL ratio did not improve. The combination of usual advice and drug treatment was as effective as intensive advice and drug treatment together and was more cost-effective than intensive advice alone.

An uncontrolled work place trial, The Dietary Alternatives Study, also examined the effect of fat-restricted diets on cholesterol levels. The trial randomized male industrial employees with hypercholesterolemia (LDL > 75th percentile for age) or combined hyperlipidemia (LDL and TC > 75th percentile for age) to 1 of 4 low-fat diets and followed them for 1 year. Subjects were also encouraged to eat more fiber. The hypercholesterolemia subjects reduced their mean LDL by 5% to 13%; the combined hyperlipidemia group reduced their LDL by 3% to 7%. There were small decreases in HDL for 2 of the hypercholesterolemia groups.

#### Meta-analysis

Tang et al conducted a meta-analysis of single intervention dietary trials conducted among free-living adults and published before 1996. ^154^ Trials of patients with known CHD and trials conducted in nonprimary care settings were included; trials of specific dietary supplements (eg, oat bran, garlic) and multirisk factor trials were excluded. These investigators found the mean reduction in cholesterol to be 5.3% at 12 months for trials of at least 6 months' duration. The American Heart Association Step One diet, advocated as the first intervention for patients with no previous CHD, produced an average reduction of 3.0%. Brunner and colleagues found a similar result (mean reduction of 3.7%) in their meta-analysis of 17 studies. ^155^

Denke reviewed older trials of dietary advice in individuals at usual and increased risk for coronary disease. ^156^ She concluded that "intensive individualized counseling" in patients at usual risk for coronary disease produced 5% to 14% reductions in TC and that 4 studies in high-risk individuals produced 4% to 17% reductions. No search strategy or methods section was provided, and several published studies that were similar to the included studies were not discussed or evaluated.

The 2 studies from the Denke review that were performed in usual-risk patients were the Diet-Heart Feasibility Study and the Women's Health Trial. ^156^ The Diet-Heart study tested the effect of a high-intensity Step Two diet in 1,000 men with initial mean TC of 230 mg/dL. They found a 10% to 12% reduction in TC after 1 year; the control group had small (4%) reductions as well. The Women's Health Trial randomized 300 women at higher risk for breast cancer (mean TC 222 mg/dL) to a Step Two diet or control to test whether reduction in dietary fat would reduce the incidence of breast cancer. The control group did not have baseline cholesterol measurement, but the intervention group had a 7% reduction in TC at 1 year compared to baseline. The control group values at 1 year were similar to the intervention group baseline values.

The 4 studies in high-risk groups included the Oslo and Multiple Risk Factor Intervention Trial (MRFIT) trials, which are discussed in the next section of the SER. The 2 other included studies were the LRC trial and the Chicago Coronary Prevention Evaluation Program (CCPEP). The LRC was a nonrandomized 90-day study that found an 8% reduction in TC. The CCPEP was a nonrandomized, uncontrolled study of 150 men at high risk for CHD who received intensive nutritional counseling and reduced their mean TC by 10% at 4 years.

The heterogeneity of the included trials and nonsystematic nature of the Denke review make it difficult to estimate the magnitude of effect from any given level of dietary counseling. Nevertheless, it is clear that at least in some cases sustained changes in TC can be maintained in highly motivated, selected subjects undergoing intensive interventions. Whether these interventions change the risk of CHD or reduce actual CHD events is unclear: the Oslo intervention reduced CHD events, but MRFIT did not. The generalizability and feasibility of these results for primary care settings are poor.

Although individualized dietary interventions have had only a modest overall impact on TC levels (mean reduction 3% to 6%) and have not demonstrated a reduction in CHD events, the mean response may mask a smaller subgroup of individuals who are able to make significantly larger changes in cholesterol levels. It is difficult to document the size of the "exceptional responder group" from the published results of studies that we identified. One earlier study by Henkin et al found that about 58% (42 of 73) of subjects reduced their TC by more than 10% over the initial 12 weeks of a trial using intensive Step One dietary advice. After 6 months, however, only 22 of 73 (30%) still had reductions of more than 10% from baseline. If the dropouts are considered to be nonresponders, this proportion is reduced to 21% (22/105).

### Effectiveness of Dietary Advice in Large Multi-Risk Factor Trials

#### Trials

We identified 5 RCTs that examined the effect of a multi-risk factor intervention on the incidence of CHD events and CHD mortality. ^157^ ^-^ ^161^ The 5 studies ranged from 5 to 10 years in duration and enrolled a total of almost 50,000 middle-aged male subjects. Four of the studies were conducted in Europe and 1 (MRFIT) in the United States. The 5 studies were published between 1981 and 1986, and hence they consider patients that may be systematically different from patients with lipid disorders today. Initial cholesterol levels, for example, were quite high, with mean values from 240 to 330 mg/dL. The intensity of dietary advice varied among the studies. In MRFIT, the most relevant study for US populations, intervention subjects initially received 10 weekly group sessions that addressed smoking, dietary advice to reduce cholesterol, and blood pressure control. Subjects and their wives then received individualized counseling every 4 months for the remainder of the study. The dietary intervention sought to reduce weight and limit the intake of saturated fat. TC was reduced by 5% among intervention subjects and by 3% in controls.

The 5 studies generally had high internal validity but fair to poor external validity, and they achieved heterogeneous results. The Goteberg, MRFIT, and World Health Organization (WHO) studies had only small net reductions (4%, 2%, and 0.5%, respectively) in mean TC, whereas the Helsinki MRF and Oslo studies achieved substantial reductions (13% and 23%, respectively). In terms of clinical endpoints, 4 of the 5 studies had no effect or a trend toward harm; in contrast, the Oslo study produced large and statistically significant reductions in CHD events. ^162^

Why did the Oslo study have such different results? The very high baseline TC levels (mean = 328 mg/dL) may be an important factor. The Oslo diet intervention mainly involved substitution of polyunsaturated fats for saturated fats. Subjects who were overweight or had elevated triglycerides were given diets that reduced caloric intake as well. Net TC was reduced by 13%, and triglycerides by 20%. HDL cholesterol increased by almost 30%. The large reduction in TC and the impressive increase in HDL cholesterol have not been repeated in other dietary intervention studies of primary prevention; moreover, these results were not seen in the MRFIT trial conducted in the United States. In addition, we cannot separate the effect of the concurrent smoking cessation advice, which may have also contributed to the reduction in CHD events.

#### Meta-analysis

Ebrahim and Smith performed a systematic review and meta-analysis of 14 multiple risk factor intervention randomized trials of at least 6 months' duration that included the studies described above plus several others. ^163^ They found, overall, that the interventions modestly decreased blood pressure and smoking. Their net effect on serum cholesterol was a reduction of 5.4 mg/dL (0.14 mmol/L). The interventions did not reduce total mortality (OR, 0.97; 95% CI, 0.92, 1.02), CHD mortality (OR, 0.96; 95% CI, 0.88, 1.04), or nonfatal MIs (OR, 1.0; 95% CI, 0.92, 1.07).

### Impact of Learning One's Cholesterol Level on the Effectiveness of Diet Therapy

A proposed rationale for screening for lipid disorders, particularly in young adults, has been that knowledge of one's cholesterol level may improve adherence to dietary advice. As documented in Evidence Table 4 (Appendix 3), our literature review identified 4 studies published between 1992 and 1998 that examined the effect of learning one's cholesterol level on the effectiveness of dietary therapy to lower TC. ^164^ ^-^ ^167^ Three were randomized trials, ^164^ ^,^ ^166^ ^,^ ^167^ and 1 was a quasi-experimental design. ^165^ In 3 of the studies, subjects were volunteers recruited from work sites; the fourth was performed in a British primary care clinic. In general, the studies were of fair quality and employed low-intensity to moderate-intensity interventions.

Little overall net reduction (percentage reduction in intervention minus percentage reduction in controls) in cholesterol levels was noted with dietary therapy among those learning their cholesterol level. Robertson et al found only a 1% net reduction among those given their cholesterol levels. ^164^ Elton et al and Hanlon et al found, respectively, 4% and 2% net reductions in cholesterol levels. ^165^ ^,^ ^166^ Strychar et al found no difference in cholesterol levels between those who were or were not told their cholesterol levels. ^167^

None of the trials was designed to measure important clinical endpoints such as a change in the incidence of CHD events. Relatively larger reductions in TC were observed for subjects with high cholesterol on initial screening; subjects with low starting cholesterol levels had no net change or small net increases in cholesterol levels. Both changes may be partially explained by regression to the mean. Given the (at-best) small net reductions in cholesterol among intervention subjects, feedback of cholesterol results does not appear to increase substantially the overall effectiveness of diet therapy, although the subgroup with elevated initial levels may benefit somewhat.

### Special Populations: Diet Therapy in Children and Adolescents

Both the National Cholesterol Education Program (NCEP) and the American Academy of Pediatrics (AAP) have advocated adoption of a low-fat diet in childhood as a means of establishing healthy lifelong dietary habits and as a population approach to lowering blood cholesterol levels. ^24^ ^,^ ^168^ The population approach aims to lower the average level of blood cholesterol in all children and adolescents by encouraging the adoption of a low-saturated fat, low-cholesterol diet. The rationale is that a relatively small reduction of mean levels of TC and LDL cholesterol in children and adolescents, if continued into adulthood, could decrease the development of atherosclerosis and substantially decrease CHD incidence.

The diet recommended by the NCEP and AAP for all healthy children over the age of 2 years is the American Heart Association Step One diet. It includes the following pattern of nutrient intake: less than 10% of total calories from saturated fatty acids, an average of no more than 30% of total calories from fat, and less than 300 mg/day of cholesterol. This contrasts with the average US diet for persons 2 months to 19 years of age as determined by the 1988 to 1991 National Health and Nutrition Examination Survey III, which found mean intakes as follows: 12% of total calories from saturated fat, 34% of total calories from fat, and approximately 270 mg/day of dietary cholesterol. ^169^

#### Children and Adolescents

The safety, efficacy, and feasibility of low-fat diets in children and adolescents remain unsettled. To address these issues, intervention studies have been carried out in specialized clinical settings, schools, and 1 primary care setting.

The Dietary Intervention Study in Children (DISC), a 3-year, multi-center RCT, used an intensive behavioral intervention to promote adherence to a low-fat diet in children (N = 663) ages 8 to 10 years who had LDL cholesterol levels between the 80th and 98th percentiles. ^170^ ^-^ ^172^ Participating children were volunteers recruited from public and private elementary schools by mass mailings to members of a health maintenance organization and from pediatric practices. Participants went through a multiple-step screening process; the total number of children screened was 44,000. The intervention was carried out by highly trained nutritionists, behaviorists, and health educators who conducted group, individual, and telephone counseling sessions with intervention families over the 3-year study period. Subjects and their families participated in a combination of 18 individual and group sessions during the first year of the intervention. During each of the second and third years, intervention children and families participated in 4 to 6 individual or group sessions with monthly telephone contacts between sessions. The primary goal of the intervention was adherence to a diet providing 28% of energy from total fat, less than 8% of energy from saturated fat, and less than 150 mg/day of cholesterol; this is similar to the American Heart Association Step Two diet.

Dietary levels of total fat, saturated fat, and cholesterol decreased significantly in the intervention group, although not to study goals. DISC achieved modest lowering of LDL cholesterol levels while maintaining adequate growth, iron stores, nutritional adequacy, and psychological well-being. ^170^ After 3 years, the mean difference in TC between intervention and control groups was 3.23 mg/dL. The serum cholesterol level in the intervention group decreased 1.6% more than in the control group. Serum HDL levels did not differ significantly between the control and intervention groups.

The Children's Health Project evaluated the effect of nutrition education programs for hypercholesterolemic children that practicing physicians could feasibly carry out. ^173^ Over a 2-year period, 3,652 children between 4 and 10 years of age and followed for care in suburban pediatric practices had a screening TC. Of those screened, 997 had elevated TC greater than 176 mg/dL (75th percentile). Of the 924 eligible children, 458 agreed to participate in confirmatory testing. Of these participants, 27l had elevated LDL cholesterol levels (between 107 to 164 mg/dL for boys and 112 to 164 mg/dL for girls) and were randomized to 1 of 2 educational interventions or to an at-risk control group. One intervention was a parent-child auto-tutorial nutrition education program that could be carried out at home; the second intervention was standard nutrition counseling delivered by a registered dietitian. The interventions were carried out in a research center in a manner that was meant to replicate a pediatric practice setting. At 1 year of follow-up, children in the intervention groups reported decreased total and saturated fat intake and maintained normal growth patterns. Baseline and 1-year follow-up values of LDL cholesterol levels did not differ among the groups.

#### Infants and Toddlers

The first 2 years of life are a period of rapid growth and development necessitating high energy intake. The NCEP and AAP do not recommend dietary modification in children under the age of 2 years. Dietary recommendations for children from NCEP and AAP have suggested introducing low-fat diets after the age of 2 years because of concerns that restricting fat intake in infancy could lead to inadequate intake and poor growth and development.

The Special Turku Coronary Risk Factor Intervention Project for Babies (STRIP) was a prospective RCT of the effects of a low-saturated-fat, low-cholesterol eucaloric diet on growth and serum lipid levels in infants and young children. ^174^ This study enrolled families of 1,062 healthy infants 7 months of age and followed them in the well-baby clinics of the city of Turku, Finland. The intervention team comprised 5 pediatricians, 3 dietitians, and a registered nurse. Intervention families were given intensive health education when the infant was 7, 8, 10, and 13 months of age; the dietitian's advice sessions lasted 20 to 45 minutes at each visit and encouraged a diet containing 30% to 35% total fat (a ratio of polyunsaturated to monounsaturated to saturated fat of 1:1:1) and dietary cholesterol of less than 100 mg/1000kcal/day.

At 13 months of age, families in the intervention group reported significantly lower daily intakes of energy and saturated fat than families of the control group. The absolute fat intake in the intervention group was lower than the researchers had expected. In addition, intervention group infants did not show the typical increase in serum lipids usually seen in this age group; in contrast, serum lipids in the control group infants did increase. Growth among these infants did not differ between the groups and was at expected rates for 13-month-old Finnish infants. ^175^

The counseling team continued to see families in the intervention group at 1- to 3-month intervals until the age of 2 years and then twice yearly. At 48 months of age, the STRIP intervention children had lower intakes of saturated fat, total fat, and cholesterol than the control children. Both groups of children were reported to be growing at normal rates. ^176^ After adjusting for lipid levels at entry into study, mean TC concentration for children 13 and 36 months of age was significantly lower in intervention subjects than in control subjects. There was a 6.3% net difference in the change in total cholesterol (8.4% increase for intervention subjects versus 14.7% for controls). When the data were analyzed by sex, the effect of the dietary intervention was significant only in boys. ^174^

In summary, although the STRIP study showed normal growth in infants on fat-restricted diets, the long-term effects of such a diet on very young children are not known. In addition, the fat intake of the infants in the STRIP study decreased below that counseled by study dietitians, suggesting that close follow-up is essential to ensure adequate growth and nutrient intake in very young children on low-fat diets. We reiterate that the NCEP and AAP do not recommend dietary modification in children under the age of 2 years.

#### School Health Interventions

The Child and Adolescent Trial for Cardiovascular Health (CATCH) was an RCT that evaluated an intensive 2-year school health program targeted at children between the third and fifth grades. ^177^ CATCH enrolled 5,106 third-grade students from 28 public schools in California, Louisiana, Minnesota, and Texas. The intervention involved modifications in school food service, enhanced physical education, and classroom health curricula.

CATCH was able to modify the fat content of school lunches, increase moderate to vigorous physical activity in physical education classes, and improve self-reported eating and physical activity habits. However, the change in blood cholesterol measures did not differ between students in the control and intervention groups.

### Harms of Dietary Interventions in Children and Adolescents

Concern about the safety of low-fat diets in children has been raised because of case series that demonstrate failure to thrive or nutritional deficiencies in infants and young children on fat-restricted diets initiated by parents. ^178^ ^,^ ^179^ An additional concern is that substituting simple carbohydrates for fat in order to maintain eucaloric intake may lead to obesity.

In addition, the monitoring of diet and lipid levels has the potential to label the child as a patient and may lead him or her to adopt "sick role" attitudes and behaviors. Also, the increased monitoring and visits necessitated by appropriate follow-up can be difficult for busy families.

#### Conclusions

In summary, clinical trials of low-fat dietary interventions in children and adolescents showed maintenance of normal growth, adequate iron stores, and nutritional adequacy. However, the interventions in the DISC and STRIP trials require a significant amount of counseling and follow-up, which may not be feasible in primary care practice because of financial and resource constraints. In addition, the close monitoring of growth and nutritional status may have contributed to the lack of adverse effects.

### Exercise and Lipids

Observational epidemiological studies have found that persons who are physically active have lower rates of CHD than persons who are inactive. ^180^ Whether these observational findings can be translated into successful and feasible interventions is not clear: no trial of exercise done in primary prevention settings has found decreased CHD events among those assigned to exercise.

Many studies have examined the impact of exercise on CHD risk factors, including lipid disorders. A meta-analysis of 95 studies found that subjects assigned to exercise had post-intervention cholesterol levels that were 7 to 13 mg/dL lower than controls. ^181^ The larger reductions were seen among patients who were able to lose weight; the smaller reductions occurred among those with no weight change. Those reporting weight gain had a small (3 mg/dL), nonsignificant increase in TC. HDL cholesterol levels increased by an average of 2 mg/dL and were not affected by the amount of weight loss.

Steptoe et al. evaluated whether brief behavioral counseling by practice nurses that was based on the stages of change model could reduce cardiovascular risk factors. ^182^ Twenty British primary care practices were randomized either to provide the intervention (2 to 3 sessions of counseling) to patients with 1 or more CHD risk factors or to act as controls. The 3 target areas were smoking cessation, dietary advice to reduce fat intake and increase fruits and vegetables (no specific percentage goal for fat intake was used), and increasing physical activity. Patients on special diets or lipid-lowering drugs were excluded. Dropout rates were high: only 54% of intervention patients and 62% of controls completed the 1-year trial.

Among trial completers, biochemically validated rates of smoking cessation, self-reported fat intake, and self-reported physical activity improved for the intervention group. The reduction in serum TC at 1 year was the same in the intervention and control groups (5.1%). The reason for the moderately large decrease in the control group is unclear, but it does not appear to be a result of diet or drug interventions in the control group. It may simply reflect regression to the mean.

### Summary of Dietary and Exercise Intervention Data

Diet therapy, including diets high in fish ^183^ and " Mediterranean" diets, ^184^ have reduced CHD events in secondary prevention settings. Low-fat diets have reduced CHD events among institutionalized patients without previous CHD. ^183^ ^,^ ^185^ They have not, as yet, been demonstrated to reduce CHD events in free-living primary prevention populations other than the Oslo trial. Controlled studies have generally achieved only modest long-term reductions in TC (3% to 6%), despite relatively intensive interventions. The small cholesterol reductions in primary prevention are in part a result of incomplete adherence. ^154^

A systematic review of studies conducted on metabolic wards found that dietary therapy can produce short-term decreases in TC of 10% to 20% ^186^ when patients are fed a controlled low-fat diet, but long-term change among free-living individuals is more difficult to achieve. ^156^ Only 20% to 40% of free-living participants in diet trials appear to achieve even short-term reductions of this magnitude. Currently, available data are insufficient to determine prospectively which patients are most likely to achieve these larger reductions.

Intensive, individualized diet therapy, such as that offered in MRFIT, appears to be relatively ineffective as a means of reducing lipid abnormalities and CHD events when compared with the secular trend toward declining average cholesterol levels that may be an effect of population-level interventions. ^161^

Knowledge of one's cholesterol level does not appear to affect the overall impact of dietary therapy, although persons with elevated cholesterol may be slightly better able to reduce their TC.

Intensive educational interventions aimed at decreasing dietary saturated fat and cholesterol and serum cholesterol levels in children have had modest effects on the adoption of a low-fat diet by children and their families and very modest, if any, effects on lowering serum cholesterol. Moreover, they may be associated with harms specific to children.

Exercise interventions considered as a whole do not appear to have a large impact on lipid levels, but some studies employing rigorous activity prescriptions and producing weight loss have shown changes in lipid profiles that may be clinically meaningful. These programs, however, have been difficult to implement widely.

## Key Question No. 3: Screening Strategies for Lipid Disorders

In persons without known CHD, the goal of screening for lipid disorders is to correctly identify those individuals who would benefit from special efforts to reduce the risk of future CHD events. The decision to screen for lipid disorders is based on the probability of finding lipid abnormality that would trigger specific intervention. This probability depends on the patient's age, gender, other cardiovascular risk factors, and the results of any previous lipid testing.

This section examines several areas of evidence that inform the decision about who to screen and what test or tests to use. These areas include the probability of finding an abnormal lipid level at different ages, the ability of different tests to reliably identify abnormal lipid levels, the accuracy of different measurements of lipid levels (along with other clinical information) for predicting CHD events, and the feasibility and acceptability of different screening strategies. The issues of monitoring lipid levels and drug dosages after the initiation of therapy or establishing treatment goals is beyond the scope of our work and is not considered in this report. Patients with known cardiovascular disease are at high risk for future events and should have their lipid levels measured(they will not be discussed further here otherwise.

### Natural History and Epidemiology of Cholesterol Levels and Lipid Disorders

#### Cholesterol in Children and Adolescents

Cholesterol levels tend to follow a typical pattern during childhood and adolescence. Data from the Bogalusa Heart Study suggest that the low serum lipid levels noted during the first 2 years of life increase rapidly; lipid levels approach adult ranges by 2 to 3 years of age but are not necessarily stable. ^187^ The STRIP study suggests that this increase can be moderated to some extent by dietary changes. ^174^ Lipid levels remain fairly stable during childhood, then decrease somewhat during early puberty. ^171^ ^,^ ^188^ ^,^ ^189^ Adolescent boys and girls both appear to experience decreases in LDL cholesterol, whereas boys also have a decrease in HDL cholesterol. ^171^ As sexual maturation is completed, lipid levels increase to adult values.

Although cardiovascular disease from atherosclerosis typically becomes apparent in middle-aged and older populations, arterial lesions of atherosclerosis begin in childhood. The Pathological Determinants of Atherosclerosis in Youth (PDAY) study identified atherosclerotic lesions in persons 15 to 34 years of age who were killed by trauma. ^190^ In addition, these investigators demonstrated that the percentage of intimal surface involved with atherosclerotic lesions in both the aorta and right coronary artery was directly associated with postmortem serum levels of LDL cholesterol and very low-density lipoprotein (VLDL) cholesterol and negatively associated with postmortem serum high-density lipoprotein cholesterol concentrations. The prognostic significance of these lesions is unclear.

The association between childhood cholesterol levels and adult cardiovascular disease has not been determined. One indirect measure of this relationship has been to study whether childhood cholesterol levels "track" into adulthood, ie, to determine whether childhood cholesterol levels accurately predict adult cholesterol levels.

Data from a cohort followed in the Bogalusa Heart Study indicate that about 50% of children (2.5 to 14 years of age) who had TC or LDL cholesterol levels above the 75th percentile at baseline continued to have TC or LDL cholesterol levels above the 75th percentile levels 12 years later. ^189^ The persistence of elevated LDL levels was greater in children 9 to 14 years of age (55%) than in those 2 to 8 years of age. The Muscatine study followed a cohort of children into adulthood. ^191^ Two cholesterol measurements taken during childhood, 1 at 10 years and 1 at 12 years, were compared with adult LDL cholesterol levels obtained between 20 and 30 years of age. Of the children with a screening cholesterol level above the 75th percentile at 10 and 12 years of age, only 46.8% had high LDL levels in adulthood. Increasing the childhood cut point to the 95th percentile increased the positive predictive value to 89.7%. Of note is that most adults with high cholesterol were not identified by the 95th percentile criterion during childhood. ^138^ ^,^ ^168^ ^,^ ^192^ ^,^ ^193^

#### Cholesterol in Adults

In adults, mean TC increases with age for both men and women. ^6^ In men, mean TC increases steadily from early adulthood to middle age and then reaches a plateau, falling only in men older than age 75 years. Mean TC is initially lower in premenopausal women than in men, but it rises at a similar rate. After menopause, however, women experience an additional 10 to 20 mg/dL rise, and their mean TC remains higher than for men throughout the remainder of life. HDL cholesterol levels do not change greatly throughout adulthood. ^194^ Mean TC and the proportion with levels greater than 240 mg/dL at any age are similar for those identifying themselves as white or African American. ^8^

##### Probability of finding an abnormal lipid level

Data from the National Health and Nutrition Examination Survey (NHANES III) can be used to estimate the likelihood of finding different lipid levels in white men and women (Figures 5 and 6). For men ages 25 to 34, the probability of finding a TC greater than 240 mg/dL is 5%; only 0.6% have a TC greater than 280 mg/dL. In men 45 to 54 years old, 27% have TC greater than 240 mg/dL and 6% greater than 280 mg/dL. Although not shown in Figure 5, men in the 55 to 64 year old cohort have a 25% probability of having TC greater than 240 mg/dL and 5% greater than 280 mg/dL. In women 25 to 34 years old, 5% have a TC greater than 240 mg/dL and 0.35% greater than 280 mg/dL. In women 45 to 54 years old, 28% have a TC greater than 240 mg/dL and 7% greater than 280 mg/dL. Although not shown in Figure 6, women in the 55 to 64 year old cohort have a 43% probability of having TC greater than 240 mg/dL and 12% greater than 280mg/dL. ^6^

Figure 5. NHANES III Phase 2 Total Cholesterol, Men

Figure 6. NHANES III Phase 2 Total Cholesterol, Women

As shown in Figures 7 and 8 for the ratio of TC to HDL (TC/HDL), 14% of men 25 to 34 years of age have a ratio greater than 6, and 2.2% have a ratio greater than 9. In men 45 to 54 years of age, 31% have a ratio greater than 6 and 1.9% greater than 9 (Not shown in Figure 7). In women, 6.7% of those 25 to 34 years of age have a ratio greater than 6 and 0.7% greater than 9, and in women 45 to 54 years of age, 7.3% are greater than 6 and 0.9% greater than 9. In women 55 to 64 years of age, 17.5% have a ratio greater than 6 and 3.8% greater than 9 (Not shown in Figure 8). ^9^

Figure 7. NHANES III Phase 2 TC/HDL Ratio, Men

Figure 8. NHANES III Phase 2 TC/HDL Ratio, Women

Figure 9. Sheffield Table

##### Mean 10-year risk of CHD events

Because individuals will have different combinations of nonlipid risk factors, the lipid level at which therapy would be initiated will vary. We applied the Framingham risk equations to the population of white men and women from NHANES III ^9^ to estimate their 10-year risk for CHD. The mean risk for men 30 to 35 years of age is 3.35% and increases steadily to 24% for men 65 to 74 years. The mean risk for women 30 to 45 years is less than 1%, rising to 11.6% for women 65 to 74 years.

##### Prevalence of familial hypercholesterolemia

The estimated prevalence of familial hypercholesterolemia or FH (Type II) is 0.2%, or 1 in 500 in the general US population. ^195^ As shown in Table 7, the risk of having a CHD event for untreated patients with familial hypercholesterolemia begins to increase at age 25 to 30 years in men and 35 to 40 years in women, and reaches 50% for men at age 50 to 60 years. ^196^ ^,^ ^197^ The prevalence of familial hypercholesterolemia among children with a TC of about 200 mg/dL is 0.07%, or 7 per 10 000 persons; even among children with a TC of 240 mg/dL, the prevalence is only 6%. ^195^

Table 7. Cumulative Incidence of Coronary Heart Disease Events in Men and Women With Type II Familial Hypercholesterolemia

Cumulative Risk of a CHD Event at Age: | Men | | | Women
| Slack, 1969 ^196^ | Stone et al, 1974 ^197^ | | Slack, 1969 ^196^ | Stone et al, 1974 ^197^
30 years | 5% | 8% | | 0% | N/R
40 years | N/R | 16% | | N/R | 9%
50 years | 51% | N/R | | 12% | 19%
60 years | 85% | 52% | | 58% | 32%

NOTE: N/R = not reported.

### Identifying Lipid Disorders in Young Adults and Children

In this section of the evidence review, we examine the ability of family history to identify children, adolescents, and young adults with lipid disorders.

#### Sensitivity of History and Examination Findings for Familial Hypercholesterolemia

In addition to the population approach of encouraging a healthy diet low in saturated fat, the NCEP and AAP recommend a "selective screening strategy" for children and adolescents. This latter strategy was adopted to identify individual children and adolescents whose elevated cholesterol levels put them at greatest risk of having high blood cholesterol as adults, thus increasing their risk of CHD. The NCEP and AAP recommend screening children and adolescents: (1) whose parents or grandparents, at 55 years of age or less, were found to have documented coronary atherosclerosis or have clinical evidence of cardiovascular, cerebrovascular, or peripheral vascular disease; (2) whose parent has an elevated blood cholesterol of 240 mg/dL or higher; or (3) whose parental or grandparental history is unobtainable or unknown, particularly those children and adolescents with other risk factors.

The data relevant to the issue of how well young persons with familial lipid disorders can be identified in the absence of universal screening depends on the sensitivity of clinical criteria in young adults. The presence of a family history of CHD events is one such criterion. The investigators in the Simon Broome study found that only 39% of men and 48% of women with FH had a paternal or maternal history of premature MI (before 55 years in men or 60 years in women). However, the investigators also found that a larger set of criteria (including the presence of other CHD risk factors or physical examination findings such as corneal arcus) would have identified 65% of the FH patients 20 to 39 years of age.

#### Sensitivity of Family History in Children and Adolescents

The previous NCEP and AAP guidelines for lipid screening and treatment in children recommended a selective screening approach based on family history of early CHD or abnormal lipid levels. This approach was felt to balance sensitivity for identifying high-risk children with consideration for the harms that could result from universal screening.

The sensitivity of parental history of MI for identifying lipid disorders in children and adolescents is compromised by the fact that the parents of the patients may not have reached ages 55 or 60 years yet. Some investigators have examined using a history of other manifestations of CHD (eg, angina, bypass surgery), the history of premature CHD in grandparents, or the finding of very high cholesterol in parents (in the absence of known CHD) to increase sensitivity.

Another limitation of the existing literature is that parental and grandparental knowledge of hypercholesterolemia may be higher today than 10 to 15 years ago when lipid screening was less common in adults. Older studies' estimates of the sensitivity of elevated parental or grandparental lipid levels may underestimate their sensitivity today, because now a large majority of adults have had their cholesterol measured. Conversely, strategies using elevated parental lipid disorders will be less able to control the number of children who are asked to have blood drawn on the basis of a "positive" history, so the difference between selective and universal screening will be smaller.

#### Studies Using a Single Case Definition

Diller et al used a community-based cohort of white male children ages 2 to 19 years to examine the sensitivity of a combination of family history of CHD (any form of CHD in parents or grandparents before age 55 years, including " angiographically demonstrated coronary artery disease") or a parental TC greater than 240 mg/dL. They found that these criteria identified 74% of children with LDL greater than 130 mg/dL and would require obtaining cholesterol levels in 48% of subjects. ^198^

Dennison et al used the Bogalusa Heart Study data to examine the sensitivity of a parental history of vascular disease (defined as previous stroke, heart attack, diabetes, or hypertension) for identifying children with LDL cholesterol above the 95th percentile. They found that the sensitivity varied by age in white children but not for African American children (Table 8). ^199^

Table 8. Sensitivity of Family History in Identifying Children and Young Adults With Lipid Disorders

Study/ Population | Lipid Level Used to Define Cases | Diagnostic Criteria | Sensitivity | Percentage Requiring Lipids Measured
NCEP/ LRC, 1992 ^96^ Children 0-19 | LDL > 130 | Parental TC > 260 Parental TC > 240 | 29.7% 40.5% | 18.3% 25.1%
Primrose et al, 1994 ^200^ Children 12-15 | TC > 200 | 1^st^ or 2^nd^ degree relative with CVD event < age 55 | 33% | N/A
Diller et al, 1995 ^198^ Children < 20 | LDL > 130 | Family history (parents or grandparents) of CHD at age < 56 | 73.9% | 47.8%
Simon Broome Register Group, 1991 ^238^ British FH patients | N/A - FH cases age 20-39 | MI in father < 55 or mother < 60 | Men 39% Women 48% | N/A
Steiner et al, 1991 ^203^ Urban HMO teen clinic- ages 12-21 | TC > 250 TC > 200 | Hyperlipidemia in parent or sibling; CHD in 1^st^ or 2^nd^ degree relative before age 65 | 82% 62% | N/A N/A
Garcia and Moodie, 1989 ^202^ | LDL > 130* | 1^st^ or 2^nd^ degree relative with MI < age 55 or known lipid disorder | 52% | N/A
Dennison et al, 1989 ^199^ Bogalusa Children 4-17 | TC > 95th percentile for age | Parental history of heart attack, stroke, diabetes, or hypertension | White 4-10 years, 38% White 11-17 years, 59% African American 4-10 years, 27% African American 11-17 years, 25% | N/A
Resnicow and Cross, 1993 ^204^ | TC > 200 mg/dL | Parental self-report of TC > 200 mg/dL | 48.5% | 34%
Benuck et al, 1992 ^205^ Children 2-13 and parents | TC > 200 mg/dL | A parent with TC > 240 mg/dL A parent with TC > 200 mg/dL | 27.5% 98% | 52% 72%
Griffin et al, 1991 ^201^ Children 2-13 | > 90th percentile | Any family history of CHD or hyperlipidemia | 51% 46% | N/A N/A

Sensitivity did not improve when cases defined as LDL > 160 or 190 mg/d

NOTE: FH = familial hypercholesterolemia; N/A = not available; CVD = cardiovascular disease; TC = total cholesterol; CHD = coronary heart disease; LDL = low-density hypoprotein; MI = myocardial infarction.

Primrose et al examined the sensitivity of a family history of a CVD event (CHD or stroke) before age 55 years for identifying Irish adolescents with TC greater than 200 mg/dL They found a sensitivity of 33%. ^200^

#### Studies Examining Different Case Definitions

At least 3 studies have stratified their results using different cut-points to define cases of hyperlipidemia in children. Griffin et al evaluated the sensitivity of family history of CHD events or hypercholesterolemia in parents or grandparents for identifying children 2 to 13 years of age with hyperlipidemia. ^201^ When hyperlipidemia was defined as an LDL cholesterol above the 90th percentile for age, sensitivity was 51%. Positive histories were not more common when cases were defined as an LDL greater than the 95th percentile (greater than 160 mg/dL).

Garcia and Moodie tested white, middle-class children ages 3 to 18 years presenting at a pediatric group practice in Ohio from 1986 to 1988. ^202^ Of 375 children with a LDL cholesterol greater than 130 mg/dL, 299 had a family member (usually parent) who completed a family history questionnaire. Family history of a first- or second-degree relative with an MI before age 55 years or a known history of hypercholesterolemia had a 52% sensitivity. Proportions were similar when subsets of children with LDL greater than 160 or 190 mg/dL were examined.

Steiner et al identified adolescents (ages 12 to 21, mean 15.6 years) from an urban health maintenance organization clinic with TC above 200 mg/dL. ^203^ Using AAP 1988 criteria, 62% of adolescents with TC above that threshold were identified. When cases were defined by a TC greater than 250 mg/dL, the 1988 criteria identified 9 of 11 patients with hyperlipidemia (82%).

#### Studies Examining the Performance of Parental Cholesterol Levels Alone

Resnicow and Cross examined the sensitivity of a parental self-report of elevated cholesterol (greater than 200 mg/dL) for identifying a TC above that level in elementary-age school children. ^204^ Sensitivity was 48.5%. Prevalence of parental cholesterol over 200 mg/dL was 34%.

Benuck et al measured the cholesterol of children ages 2 to 13 and their parents (50% had not previously known their cholesterol level). ^205^ They found that 98% of children with TC greater than 200 mg/dL had a parent with TC values above that level. However, the overall prevalence of parental cholesterol greater than 200 mg/dL was 72%. The proportion of children whose parents had cholesterol levels greater than 240 mg/dL was lower: 27.5%.

The NCEP performed novel data analyses for the Report of the Expert Panel on Blood Cholesterol levels in Children and Adolescents. ^3^ They found that parental TC greater than 260 mg/dL identified 30% of children with LDL cholesterol greater than 130 mg/dL. Using parental TC greater than 240 mg/dL increased the sensitivity to 40% and required testing 25% of children as opposed to 18% with the higher cut point.

#### Screening Accuracy in Children

In a cohort of families participating in an epidemiologic study, family history of premature cardiovascular disease had a positive predictive value of only 7% in identifying children with LDL cholesterol levels greater than 130 mg/dL (95th percentile). ^198^ Combining positive family history with parental cholesterol levels greater than 240 mg/dL increased the positive predictive value to 15.3%.

#### Conclusions

The performance of various criteria for identifying lipid disorders in young persons varies widely, with sensitivity values reported from 27% to 98%. The higher sensitivity values generally required more persons to have their lipid levels measured (lower specificity). Performance appeared to be higher for older subjects, although African American children in the Bogalusa study did not follow this trend. In the studies that used different case definitions, test performance did not appear to improve when "cases" were defined by more extreme lipid levels such as TC greater than 250 mg/dL. These studies were carried out in younger populations, however, which may confound the effect of case definition on sensitivity. Currently, selective screening of children seems to be able to identify about 50% of children with abnormal lipid levels (TC or LDL) and requires screening one quarter to one third of all children.