# Introduction

## Background

### Burden of Suffering

Certain patterns of blood lipids -including elevated total cholesterol (TC), elevated low-density lipoprotein cholesterol (LDL), and low levels of high-density lipoprotein (HDL) cholesterol-are important risk factors for coronary heart disease (CHD). ^1^ ^-^ ^3^ CHD is the leading cause of morbidity and mortality in the United States, causing nearly 500,000 deaths each year and requiring nearly 12 million hospital days of care per year. It is the leading cause of disabled life-years and is second only to injuries as a cause of life-years lost. ^4^ The age-adjusted annual death rate for CHD is 100 per 100,000 persons overall and 140 per 100,000 persons among African Americans. ^5^ ^,^ ^6^ The lifetime risk of having a CHD event, calculated at age 40, is estimated to be 49 % for men and 32 % for women in the United States. ^7^ CHD accounted for $78 billion in health care costs in 1995. ^4^

### Epidemiology

Lipid disorders are common in the United States and other Western, developed countries. Data from the National Center for Health Statistics collected from 1988 to 1994 show that 17.5% of US men and 20% of US women 20 to 74 years of age had TC levels greater than 240 mg/dL. The mean TC was 202 mg/dL for men and 204 mg/dL for women. ^5^ Approximately 6% of US men have a TC less than 200 mg/dL and an HDL cholesterol less than 35 mg/dL; 5% have a TC of 200 to -239 mg/dL and an HDL less than 35 mg/dL. ^8^ Lipid measurements performed in the second phase of the National Health and Nutrition Examination Survey (NHANES III) between 1991 and 1994 found that 28% of white men ages 35 to 65 years and 12% of white women ages 45 to 65 years had TC:HDL cholesterol ratios of greater than 6:1. ^9^ Elevated TC (greater than 200 mg/dL) was responsible for 27% of CHD events in men and 34% in women in the Framingham cohort. ^10^

Data from the screening portion of the Multiple Risk Factor Intervention Trial (MRFIT), ^2^ the Framingham study, ^1^ and an overview of observational studies ^9^ show, for middle-aged men and women, a continuous graded relationship between TC and CHD. Elevated TC confers less relative risk in the elderly. However, the absolute risk is higher for the elderly, and thus the total number of potentially preventable CHD events remains high. ^11^ The relationship between lipid disorders and CHD is examined in more depth in Chapter 3.'s section on screening.

### Health Care Interventions

The large burden of disease from CHD and strong epidemiologic associations between CHD and abnormal lipid levels have prompted efforts to modify or reduce the risk of CHD events by treating lipid disorders. In this report, we examine the evidence concerning the benefits and harms of drug, diet, and exercise therapy in treating lipid disorders and reducing the risk of CHD events in patients with lipid disorders. The underlying goal of screening and therapy for lipid disorders is to reduce the burden of illness from CHD. Thus, other means of reducing CHD, such as hypertension prevention and control, smoking prevention and cessation, and possibly chemoprophylaxis with aspirin, must be considered along with treatment of lipid disorders in patients at risk for CHD.

This review focuses on interventions that are delivered to individuals or small groups. Population-level interventions, such as changes in the fat content of foods, are not within the scope of this guide; they are addressed by the Centers for Disease Control and Prevention. In some cases, however, these population-level interventions may act as the de facto comparators for individual interventions such as dietary advice therapy. Some of the interventions considered here, such as dietary advice or exercise therapy, may also have beneficial effects on CHD or other health problems that are mediated through means other than the modification of lipid disorders. The CDC Task Force is also considering these effects. Because of the important health impact of CHD and the role of lipid disorders in its development, routine universal or targeted screening for lipid disorders has been advocated. ^3^ ^,^ ^12^ Data from the Behavioral Risk Factor Surveillance Survey show that measurement of serum cholesterol has become a common practice: 74% of adults report that they have had their cholesterol level measured, and 66% report that they have done so within the past year. The likelihood of having had one's cholesterol measured within 5 years increases with age: 40% of adults ages 18 to 24 years have been checked, compared with 66% of those 35 to 44 years and 87% of those 65 years and older. Overall, 29% of adults report that their providers have told them that they have elevated cholesterol levels. ^5^

### Prior Recommendations

Currently, little controversy exists about the benefit of testing for lipid abnormalities among patients with known CHD and treating them appropriately with drug and diet therapy (secondary prevention). The Scandinavian Simvastatin Survival Study (4S), a large trial of middle-aged men and women with CHD and elevated levels of LDL cholesterol, found that treatment reduced the risk of CHD events by 34% and the risk of CHD death by 42% . ^13^ Total mortality was reduced in men but not in women. ^14^ More recent trials conducted in men and women (including older adults 65 to 75 years of age) with modest elevations in LDL cholesterol, ^15^ ^-^ ^17^ or low levels of HDL cholesterol, ^18^ have also demonstrated a benefit from drug treatment for lipid disorders after CHD is present. However, many studies have documented low rates of treatment for patients with known CHD. ^19^

The decision about who should be screened and treated for lipid disorders in the absence of known CHD remains somewhat controversial, especially for those adults and children at low short-term risk of CHD events. The second edition of the Guide to Clinical Preventive Services from the US Preventive Services Task Force (USPSTF) gave a "B" recommendation to "periodic" screening for high TC in men 35 to 65 years of age and women 45 to 65 years of age. ^12^ The USPSTF at that time found insufficient evidence to recommend for or against TC screening in asymptomatic adults over 65 years of age, young adults, adolescents, and children. They also found insufficient evidence to recommend for or against screening for other lipid abnormalities such as low HDL or elevated triglycerides.

The National Cholesterol Education Program Adult Treatment Panel II (NCEP) guidelines recommended screening all adults 20 years of age and older with serum TC and with serum HDL "if accurate results are available" every 5 years. ^3^ The American College of Physicians found "periodic" screening for men 35 to 65 years of age and women 45 to 65 years of age to be "appropriate but not mandatory." Screening young men and women was recommended only where the history or physical exam suggested a familial disorder or there were at least 2 other CHD risk factors. ^20^ ^,^ ^21^ The Canadian Task Force on Preventive Health Care in 1994 recommended "case-finding" in all men ages 30 to 59 years who present to their health care providers and clinical judgment in other cases. ^22^ The American Diabetes Association recommends screening all adult diabetics yearly with TC, LDL, HDL, and triglycerides. ^23^

The NCEP Report of the Expert Panel on Blood Cholesterol Levels in Children and Adolescents ^24^ and the American Academy of Pediatrics Committee on Nutrition Policy Statement on Cholesterol in Children ^25^ recommended 2 approaches: (1) a low-fat diet in all healthy children over the age of 2 years and adolescents, equivalent to the American Heart Association Step One diet; and (2) selective screening (based on family history of elevated cholesterol or premature CHD) and treatment of children who are at highest risk for the development of accelerated atherosclerosis in early adult life.

## Analytic Framework and Key Questions

The RTI-UNC Evidence-based Practice Centers, together with members of the third USPSTF and other clinical and methodologic experts, sought to clarify issues concerning screening for and treatment of lipid disorders by performing a systematic review of the relevant scientific literature on these topics. This systematic evidence review (SER) specifically updates Chapter 2. (pages 15-38) of the second Guide to Clinical Preventive Services produced in 1996 by the second USPSTF. ^12^ A shorter version of this review appeared in the American Journal of Preventive Medicine in early 2001. ^26^

### Analytic Framework

This SER examines the issue of screening for lipid disorders among patients with no previous history of recognized CHD-that is, primary prevention. Figure 1 depicts a comprehensive analytic framework for this topic.

Figure 1. Screening for Lipid Disorders: Analytic Framework and Key Questions

The analytic framework begins with population(s) of persons without known CHD and moves through screening to identify persons with lipid disorders that put them at increased risk of CHD, to treatment with drugs, diet, exercise, or combinations of the three; change in abnormal lipid levels; and finally to outcomes such as reduced CHD events or deaths. Apart from the key clinical questions to be addressed (see following), this analytic framework also notes 2 points at which adverse effects or harms may arise: as sequelae to screening (eg, labeling) and as consequences of treatment (eg, direct harms from therapy or economic costs).

### Key Questions

No trials have directly examined the (implied) overarching question of whether screening for lipid disorders among asymptomatic persons leads to improvement in CHD mortality or morbidity. The decision to screen for lipid disorders in such populations is, therefore, based on data that address 2 intermediate steps (ie, linkages in the analytic framework): the effectiveness of screening to detect lipid disorders and the effectiveness of treating lipid disorders to reduce CHD events. Three key questions arise from this framework.

Key Question No. 1. Will treatment with drug therapy of patients (similar to those who would be identified by screening) without known CHD but with "abnormal" lipid levels improve outcomes compared with no treatment?

Key Question No. 2. Will treatment with diet or exercise therapy of patients (similar to those who would be identified by screening) without known CHD but with "abnormal" lipid levels improve outcomes compared with no treatment?

Key Question No. 3.Is there a reliable, accurate, acceptable, and feasible screening test (or tests) that can be used to detect lipid disorders? If so, who should be screened, and how often should screening be performed?

Apart from these core issues, we address issues relating to short-, medium-, and long-term harms of identifying patients with lipid disorders and treating them with drugs and diet therapy. In each case, the harms are considered along with the benefits to allow better judgment of the net effect of screening and therapy.

The drug therapies for Key Question No. 1 are compared with placebo pills. Clinically, the strategy of drug therapy for primary prevention can be considered to be a comparison against initiation of drug therapy only after CHD is known to be present (secondary prevention). For Key Question No. 2, most of the trials of diet and exercise therapy usually compare the intervention with a control group that receives minimal or no intervention. In some cases, these comparisons may be affected by ongoing secular trends or population-level interventions common to each group.

## Organization of This Systematic Evidence Review

Chapter 2. provides an overview of our methods for producing the SER. Chapter 3. presents the results of our literature search and synthesis organized by the 3 Key Questions. These results, and their ramifications for future research and the general limitations to this literature, are discussed further in Chapter 4. Tables and figures will be found at the end of each chapter where they are first introduced. Appendices 1 and 2 provide additional information on our methods and the system for grading articles and rating the overall strength of the evidence; and Appendix 3 contains the evidence tables developed from the literature synthesis.