# Appendix 3 Evidence Tables

Evidence Table 1. Studies of Cholesterol Reduction with Drug Therapy in Primary Care

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
Lipid Research Clinics Program, 1984^96^* | [underlined: Mean Age:] 48 y [underlined: % Female:] 0 [underlined: % White:] 95.5 [underlined: Mean BMI:] 26.25 [underlined: % HTN:] 0 [underlined: Mean SBP (mm Hg):] Total: 119.6 [underlined: Mean DBP (mm Hg):] Total: 78.2 [underlined: % Smokers]: Total: 38 [underlined: Initial TC (mg/dl)] Interven: 291.5 Control: 291.8 | [underlined: Start] Interven: 1,906 Control: 1,900 [underlined: End] Interven: NR Control: NR Total: NR | [underlined: Inclusion]: men ages 35-59 with TC > 265 and LDL > 190 [underlined: Exclusion:] history of MI or angina; angina on ETT; CHF; abnormal EKG; diabetes; hypothyroidism; liver disease; nephrotic syndrome; hyperuricemia; hypertension; cancer | Duration: 7.4 y [underlined: Study Design]: Placebo controlled, double-blind, multi-site clinical trial
Helsinki (HHS): Frick et al., 1987^97^ | [underlined: Mean Age:] 47 y [underlined: % Female:] 0 [underlined: % White:] ~100 [underlined: Mean BMI:] 26.6 [underlined: % HTN:] 15 [underlined: Mean SBP (mm Hg)]: Total: 141.7 [underlined: Mean DBP: (mm Hg)]: Total: 91.25 [underlined: % Smokers]: Total: 36 [underlined: Initial TC (mg/dl)] Total: 288.9 | [underlined: Start] Interven: 2,051 Control: 2,030 [underlined: End] Interven: NR Control: NR Total: 2,859 (no diff between grps) | [underlined: Inclusion]: healthy Finnish men ages 40-55 (civil service or industrial employees) with non-HDL chol > 200 [underlined: Exclusion]: clinical evidence of heart disease (angina or MI); CHF; abnormal EKG | [underlined: Duration:] 5 y [underlined: Study Design]: Random sampling, placebo controlled, double-blind, multi-site clinical trial
| Results
Interventions | Lipids | Total & CHD Events | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
[underlined: Interven:] cholestyramine (24g qd) [underlined: Control:] placebo [underlined: Both Grps:] moderate cholesterol-lowering diet | [underlined: % Net Reduction TC:] 8.5% | [underlined: Total Mortality %] Interven: 3.6 Control: 3.7 [underlined: CHD Mortality Rate]Interven: 1.6 Control: 2 | [underlined: Definition:] Total CHD Events Interven: 8.1 (5.5)** Control: 9.8 (6.6)** [underlined: RRR] Interven: 19% 95% CI for RRR 3 - 32% p value NR [underlined: ARR] Interven: 1.7 (1.1)** [underlined: NNT] 59 (91)** | [underlined: Internal Validity] good [underlined: External Validity] fair [underlined: Quality Grade] fair
[underlined: Interven:] gemfibrozil (600 mg bid) [underlined: Control:] placebo [underlined: Both Grps:] cholesterol-lowering diet | [underlined: % Net Reduction TC:] 11% | [underlined: Total Mortality %] Interven: 2.19 Control: 2.07 [underlined: CHD Mortality Rate] Interven: 0.68 Control: 0.94 | [underlined: Definition:] Total CHD Events Interven: 5.5 Control: 7.9 [underlined: RRR] Interven: 34% 95% CI = 8 - 53% p < 0.02 [underlined: ARR] Interven: 1.4% [underlined: NNT] Interven: 71 | [underlined: Internal Validity] good [underlined: External Validity] fair [underlined: Quality Grade] fair
Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
WOSCOPS: Shepherd et al., 1995^98^*** | [underlined: Mean Age:] 55 y [underlined: % Female:] 0 [underlined: % White:] ~100 [underlined: Mean BMI:] 26 [underlined: % HTN:] 15 [underlined: Mean SBP (mm Hg):] Total: 135.5 [underlined: Mean DBP: (mm Hg):] Total: 84 Control: NR [underlined: % Smokers] Interven: 44 Control: 34 [underlined: Initial TC (mg/dl)] Total: 272 | [underlined: Start] Interven: 3,302 Control: 3,293 [underlined: End] Interven: ~2,278 Control: ~2,305 | [underlined: Inclusion]: men ages 45-64 with "elevated LDL cholesterol" [underlined: Exclusion]: history of MI; pathologic q waves on EKG; atrial fibrillation on EKG | [underlined: Duration:] 4.9 y [underlined: Study Design]: Random sampling, placebo controlled, double-blind, multi-site clinical trial
TexCAPS: Downs et al., 1998^99^ | [underlined: Mean Age:] 58 y [underlined: % Female:] 15 [underlined: % White:] 89 [underlined: Mean BMI:] 27.05 [underlined: % HTN:] 22 [underlined: Mean SBP (mm Hg):] Total: 138 [underlined: Mean DBP (mm Hg):] Total: 78 [underlined: % Smokers]: Total: NR [underlined: Initial TC (mg/dl)] Total: 221 | [underlined: Start] Interven: 3,304 Control: 3,301 [underlined: End] Interven: 2,335 Control: 2,081 | [underlined: Inclusion]: men and women ages 45-73 for men and > 55 for women with "average TC and below average HDL" [underlined: Exclusion]: History of MI, or angina, claudication, CVA, or TIA; nephrotic syndrome; DM (on insulin); uncontrolled HTN | [underlined: Duration:] 5.2 y [underlined: Study Design]: Random sampling, placebo controlled, double-blind, multi-site clinical trial
| Results
Interventions | Lipids | Total & CHD Events | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
[underlined: Interven:] pravastatin (40 mg qd) [underlined: Control:] placebo Both Grps: diet advice | [underlined: % Net Reduction TC:] 20% (based on actual use, not intention to treat) | [underlined: Total Mortality %] Interven: 3.2 Control: 4.1 [underlined: CHD Mortality Rate] Interven: 1.6 Control: 2.3 | [underlined: Definition:] Total CHD Events Interven: 5.5 Control: 7.9 [underlined: RRR] Interven: 31% 95% CI = 17 - 43% p < 0.001 [underlined: ARR] Interven: 2.4 [underlined: NNT] Interven: 42 | [underlined: Internal Validity] good [underlined: External Validity] fair-good [underlined: Quality Grade] good
[underlined: Interven:] lovastatin titrated(20-40 mg qd) [underlined: Control:] placebo (dummy-titrated) Both Grps: Step One Diet | [underlined: % Net Reduction TC:] 18% (at 1 y) | [underlined: Total Mortality %] Interven: 4.6 Control: 4.4 [underlined: CHD Mortality Rate] Interven: 0.5 Control: 0.7 | [underlined: Definition:] Total CHD Events Interven: 3.4 (1.65)** Control: 5.45 (2.9)** [underlined: RRR] Interven: 37% (43)** 95% CI = 21 - 50% p < 0.001 [underlined: ARR] Interven: 2.05 (1.25)** [underlined: NNT] Interven: 49 (80)** | [underlined: Internal Validity] good [underlined: External Validity] good [underlined: Quality Grade] good

Note: Event rates are cumulative percentages with event over the study. Absolute Risk Reduction, Number Needed to Treat and Relative Risk Reduction are for the main outcome.

*Numbers in parentheses are 5-year outcomes for LRC

** Without unstable angina and numbers in parentheses are for nonfatal MI & CHD death

*** 5% of patients had angina

Evidence Table 2. Studies of Cholesterol Reduction with Diet Therapy in Primary Care

Source: Author, Year | Study Population | | Size of Intervention & Control Groups | Study Population Diagnosis/Condition
Roderick et al., 1997^144^ | Mean Age: 47.3 y % Female: 50 % Racial Groups: NR Setting: Primary care clinic Mean BMI Interven: NR Control: NR Total: 26.1 HTN Interven: NR Control: NR | Mean SBP (mm Hg) Interven: 124 Control: 125 Mean DBP (mm Hg) Interven: 78 Control: 77 % Smokers Interven: 26 Control: 30 Initial TC (mg/dl) Interven: 241 Control: 244 | Start Interven: 473 Control: 483 End Interven: 407 Control: 357 | Inclusion: adults ages 35-59 from general practices in four geographic areas Exclusion: severe psychiatric disease, pregnancy, terminal illness
Bakx et al., 1997^148^ | Mean Age: NR % Female: NR % Racial Groups: NR Setting: Primary care clinic Mean BMI Interven: NR Control: NR Total: 25.4 HTN Interven: NR Control: NR | Mean SBP (mm Hg) Interven: 144 Control: 150 Mean DBP (mm Hg) Interven: 88 Control: 92 % Smokers Interven: 60 Control: 54 Initial Total Chol (mg/dl) Interven: 244 Control: 237 | Start Interven: NR Control: NR End Interven: 360 Control: 112 | Inclusion: Finnish family practice patients with high risk of CHD Exclusion: NR
OXCHECK: (no author), 1994^149^and 1995^150^ | Mean Age: 49.3 y % Female: NR % Racial Groups: NR Setting: Primary care clinic Mean BMI Interven: NR Control: NR Total: NR HTN Interven: NR Control: NR | Mean SBP (mm Hg) Interven: NR Control: NR Mean DBP (mm Hg) Interven: NR Control: NR % Smokers Interven: NR Control: NR Initial Total Chol (mg/dl) Interven: NR Control: NR | Start Interven: 2776 Control: 2783 End Interven: 1660 Control: 1916 | Inclusion: adults ages 35-64 who were members of 1 of 5 general practices in Bedfordshire Exclusion: NR

Evidence Table 2. Studies of Cholesterol Reduction with Diet Therapy in Primary Care

| | Results
Study Design & Characteristics | Interventions | Lipids | Quality Considerations
Random sampling Duration: 1 y | Interven: Dietary advice from a specially trained nurse; medium intensity Control: Usual care (written booklets) | Final TC (mg/dl) Interven: 232 Control: 244 % Change in TC Interven: -3.7% Control: 0% Net Diff in mg/dl -7.8 (-15.5, 5.0) Net % Change -3.7% p value NS | Internal Validity Fair External Validity Fair Quality Grade Fair
Consecutive patients Duration: 17 y | Interven: 1 year of bimonthly diet advice (given 1978); medium intensity Control: Usual care | Final TC (mg/dl) Interven: 252 Control: 252 % Change in TC Interven: 3.3% Control: 6.3% Net Diff in mg/dl -7.8 (CI not reported) Net % Change -3.0% p value NS | Internal Validity Poor External Validity Fair Quality Grade Fair
Random sampling Duration: 4 y | Interven: Health check in 1989; (diet therapy, low intensity) Control: No health check in 1989 | Final TC (mg/dl) Interven: 232 Control: 243 % Change in TC Interven: NR Control: NR Net Diff in mg/dl -7.37 (-4.66, -10.1) Net % Change -3.1% p value NR | Internal Validity Good External Validity Fair Quality Grade Fair

Evidence Table 2. Studies of Cholesterol Reduction with Diet Therapy in Primary Care

Source: Author, Year | Study Population | | Size of Intervention & Control Groups | Study Population Diagnosis/Condition
Baron et al., 1990^151^ [Results for men only] | Mean Age: 42 y % Female: 0 % Racial Groups: NR Setting: Primary care clinic Mean BMI Interven: 25.1 Control: 24.4 Total: NR HTN Interven: 12% Control: 14% | Mean SBP (mm Hg) Interven: NR Control: NR Mean DBP (mm Hg) Interven: NR Control: NR % Smokers Interven: 32 Control: 48 Initial Total Chol (mg/dl) Interven: 191 Control: 187 | Start Interven: 97 Control: 92 End Interven: 77 Control: 79 | Inclusion: members of a geographically defined general practice Exclusion: severe psychosis, debilitating chronic illness, chronic GI disease
Lindholm et al., 1995^152^ | Mean Age: 48.7 y % Female: 15 % Racial Groups: NR Setting: Primary care clinic Mean BMI Interven: NR Control: NR Total: 27.1 HTN Interven: NR Control: NR | Mean SBP (mm Hg) Interven: 132 Control: 131 Mean DBP (mm Hg) Interven: 82 Control: 82 % Smokers Interven: 52 Control: 49 Initial Total Chol (mg/dl) Interven: 264 Control: 264 | Start Interven: 339 Control: 342 End Interven: 306 Control: 320 | Inclusion: adults ages 30-59 with 2 or more CV risk factors; cholesterol 6.5-7.79 mmol/L Exclusion: NR
Family Heart Study: Pyke et al., 1997^153^ [Results for men only] | Mean Age: 51.5 y % Female: 0 % Racial Groups: NR Setting: Primary care clinics Mean BMI Interven: NR Control: NR Total: NR HTN Interven: NR Control: NR | Mean SBP (mm Hg) Interven: NR Control: NR Mean DBP (mm Hg) Interven: NR Control: NR % Smokers Interven: 24 Control: 24 Initial TC (mg/dl) Interven: NR Control: NR | Start Interven: 2,011 Control: 2,174 End Interven: 1,767 Control: 2,174 | Inclusion: Britiol general practice patients Exclusion: NR

Evidence Table 2. Studies of Cholesterol Reduction with Diet Therapy in Primary Care

| | Results
Study Design & Characteristics | Interventions | Lipids | Quality Considerations
Random sampling Duration: 1 y | Interven: Dietary advice; medium intensity Control: No advice | Final TC (mg/dl) Interven: 175 Control: 175 % Change in TC Interven: -8.4% Control: -6.4% Net Diff in mg/dl NR Net % Change -2.0% p value NS | Internal Validity Good External Validity Fair Quality Grade Fair
Volunteers Duration: 1.5 y | Interven: Dietary advice; high intensity Control: Usual dietary advice | Final TC (mg/dl) Interven: NR Control: NR % Change in TC Interven: NR Control: NR Net Diff in mg/dl 5.82 (1.6, 10.0) Net % Change -2.2% p value NR | Internal Validity Good External Validity Fair Quality Grade Fair
Duration: 1 y | Interven: Nurse-led health check with targeted dietary advice Control: None | Final TC (mg/dl) Interven: 5.58 Control: 5.72 % Change in TC Interven: NR Control: NR Net Diff in mg/dl -0.13 Net % Change2.3% p value NR | Internal Validity Good External Validity Fair Quality Grade Fair

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
MRFIT: Neaton et al., 1992^2^ | Mean Age: 46 y % Female: 0 % HTN: 62 Setting: Other Initial TC mg/dl Interven: 240 Control: 240 Initial HDL mg/dl Interven: 42 Control: 42 | Start Interven: 6,428 Control: 5,438 End Interven: NR Control: NR | Inclusion: men ages 35-57 at increased risk of death from CHD Exclusion: known CHD, angina, diabetes (on meds or symptoms), Chol > 350 mg/dl, DBP > 115 mm Hg, > 150% IBW | Volunteers Duration: 6 y
WHO: (no author), 1986^158^ | Mean Age: 48.5 % Female: 0 % HTN: N/A Setting: 66 factories in Europe Initial TC mg/dl Interven: NR Control: NR Initial HDL mg/dl Interven: NR Control: NR Mean BMI: 25.5 kg/m^2^% Smokers: 16% | Start Interven: 30,489 Control: 26,971 End Interven: NR Control: NR | Inclusion: factory workers ages 40-59 from 4 European countries Exclusion: NR | Random Sampling Duration: 6 y

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

| Results
Interventions | Lipids | CHD Events and Mortality | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
Interven 1: Diet therapy Interven 2: Individual counseling including intensive treatment of HTN and smoking cessation Control: Usual care | Final TC Interven: 228 mg/dl Control: 233 mg/dl % Change in TC Interven: 5.0% Control: -2.9% Net % Change -2.0% p = < 0.01 Final HDL Interven: 41.7 Control: 41.9 | Total CHD Events Interven: NR Control: NR % Diff (Adj) NR CHD Mortality Interven: 1.79 Control: 1.93 p value NS Nonfatal MI Interven: NR Control: NR Total Mortality Interven: 4.12 Control: 4.04 Diff in Total Mortality .8 p value NS | Definition: CHD mortality RRR Main Outcome: 7.2% ARR Main Outcome: 0.14% NNT: 714 | Internal Validity Good External Validity Fair Quality Grade Good
Interven 1: Diet therapy Control: No tx | Net % Diff in TC -0.5% | Total CHD Events Interven: 3.08 Control: 3.27 % Diff (Adj) -10.2% p = 0.07 CHD Mortality Interven: 1.41 Control: 1.50 Nonfatal MI Interven: 1.93 Control: 2.11 Total Mortality Interven: 4.34 Control: 4.40 % Change in Total Mortality (adjusted for clustering) Interven: -5.3% p = 0.4 | Definition: CHD mortality RRR Main Outcome: 6.9% (-19, 7) p value NS ARR Main Outcome: 0.09% NNT: 1,111 | Internal Validity Good External Validity Poor Quality Grade Fair

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
Oslo: Hjermann et al., 1981^159^ | Mean Age: 45 y % Female: 0 % HTN: 22% Setting: Community Population Initial TC mg/dl Interven: 328 Control: 329 Initial HDL mg/dl Interven: 28.5 Control: 28.7 Mean BMI: NR % Smokers: NR | Start Interven: 604 Control: 628 End Interven: 590 Control: 625 | Inclusion: men ages 20-49 at high risk of CHD Exclusion: known CHD, angina, diabetes, cancer, "disabling disease," alcoholism, psychiatric disease | Volunteers Duration: 5 y

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

| Results
Interventions | Lipids | CHD Events and Mortality | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
Interven 1: Diet therapy Interven 2: Smoking cessation advice Control: No tx | Final TC Interven: 263 mg/dl Control: 341 mg/dl % Change in TC Interven: -19.8% Control: 3.6% Net % Change -23.4% p = < 0.01 Final HDL Interven: 50.1 mg/dl Control: 42.2 mg/dl % Change in HDL Interven: 76% Control: 47% Net % Change 29% p value NR | Total CHD Events Interven: 3.1 Control: 5.7 % Diff (Adj) NR CHD Mortality Interven: 1.0 Control: 2.2 Change in CHD Mortality Interven: 54.5 Nonfatal MI Interven: 2.2 Control: 3.5 Total Mortality Interven: 2.6 Control: 3.8 Change in Total Mortality Interven: -31.6 p = 0.246 | Definition: Total CHD events RRR Main Outcome: 45.6% p = 0.038 ARR Main Outcome: 2.6% NNT: 38 | Internal Validity Good External Validity Poor Quality Grade Fair

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
Goteberg MRF: Wilhelmsen et al., 1986^160^ | Mean Age: 51 y % Female: 0 % HTN: NR Setting: Community Population Initial Total Chol mg/dl Interven: 250 Control: 250 Initial HDL mg/dl Interven: NR Control: NR Mean BMI: NR % Smokers: NR | Start Interven: 7,455 Control: 2,501 End Interven: NR Control: NR | Inclusion: all men born 1915-1922 or 1924-1925 in Goteberg, Sweden Exclusion: None | Random sampling Duration: 10 y

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

| Results
Interventions | Lipids | CHD Events and Mortality | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
Interven 1: Diet therapy Interven 2: Treatment of HTN and smoking Interven 3: Drug therapy if chol remained over 300 Control: No Tx | Final TC Interven: 234 mg/dl Control: 235 mg/dl % Change in TC Interven: -6.5% Control: -6.3% Net % Change -0.2% p value NS | Total CHD Events Interven: 8.4% Control: 8.4% % Diff (Adj) NR CHD Mortality Interven: 4.6% Control: 4.5% Nonfatal MI Interven: 5.0% Control: 4.9% Total Mortality Interven: 12.9% Control: 13.0% Change in Total Mortality Interven: 0.8% Change in CHD Mortality Interven: 0 Cumulative incidence over trial | Definition: Total CHD events RRR Main Outcome: 0 ARR Main Outcome: 0 NNT: N/A | Internal Validity Good External Validity Poor Quality Grade Fair

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
Helsinki MRF: Miettinen et al., 1985^161^ | Mean Age: 48 y % Female: 0 % HTN: 33% Setting: Other Initial Total Chol Interven: 275 Control: 275 | Start Interven: 612 Control: 610 End Interven: 575 Control: 580 | Inclusion: businessmen born 1919-1934 in Helsinki, having at least 1 CV risk factor Exclusion: known CHD, angina, diabetes (glucose > 180 or req. drugs), SBP > 200, DBP > 115, EKG abn., malignancy, psychiatric disease | Volunteers Duration: 5 y

Evidence Table 3. Study Characteristics of Multiple Risk Factor Interventions Including Diet

| Results
Interventions | Lipids | CHD Events and Mortality | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
Interven 1: Diet therapy and exercise program Interven 2: Smoking cessation advice Interven 3: Drug therapy for HTN and lipids Control: Given test results and referred to their own physician | Final TC Interven: 260 mg/dl Control: 295 mg/dl % Change in TC Interven: -5.5% Control: 7.3% Net % Change -12.8% p = < .01 | Total CHD Events Interven: 3.1 Control: 1.5 P value NR CHD Mortality Interven: 0.7 Control: 0.2 Nonfatal MI Interven: 2.5 Control: 1.3 Total Mortality Interven: 1.6 Control: 0.8 Change in Total Mortality Interven: NR Change in CHD Mortality Interven: NR Nonfatal stroke Interven: 0 Control: 1.3% | Definition: Total CHD events RRR Main Outcome: NR ARR Main Outcome: -1.6% NNT: -62 | Internal Validity Good External Validity Poor Quality Grade Fair

Evidence Table 4. Impact of Learning One's Cholesterol Level

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
Robertson et al., 1992^164^ | Mean Age: N/A % Female: Interven: 54 Control: 63 Setting: Primary care/Community clinic % Smokers: 25 Initial TC mg/dl Interven: 223 Control: 215 | Start Interven: 297 Control: 281 End Interven: N/A Control: N/A | Inclusion: patients attending their general practice office ages 25-64 Exclusion: chol > 380 | Consecutive Duration: 3 mos
Elton et al., 1994^165^ * | Mean Age: 38 % Female: Interven: 40 Control: 44 Setting: Other % Smokers: 18 Initial TC mg/dl Interven: 277 Control: 276 | Start Interven: 239 Control: 256 End Interven: 229 Control: 240 | Inclusion: employees of an industrial company in Manchester, UK Exclusion: age < 20 or > 65, previous knowledge of one's chol level | Volunteers from industrial company Duration: 13 wks Quasi-experimental design
Hanlon et al., 1995^166^ | Mean Age: N/A % Female: 12 Setting: Other % Smokers: 36 Initial TC mg/dl Interven: 227 Control: 225 | Start Interven: 263 Control: 233 End Interven: 211 Control: 193 | Inclusion: employees at two engineering factories in Glasgow ages 20 - 65 Exclusion: taking lipid-lowering agents | Volunteers Duration: 5 mos F/U visit at 1 y
Strychar et al., 1998^167^ | Mean Age: 50 y % Female: 34 Setting: Other % Smokers: 37 Initial TC mg/dl Interven: 198 Control: 210 | Start Interven: ~250 Control: ~250 End Interven: 216 Control: 213 | Inclusion: employees at 6 hospitals Exclusion: using medication for chol, HTN, CHD, pregnant women, diabetes, initial chol > 300 | Volunteers Duration: 16 - 20 wks

*Quasi-experimental design. Results presented here only for subects with initial cholesterol > 250. Subjects with lower initial cholesterol levels showed no effect or had small increases compared with controls.

Evidence Table 4. Impact of Learning One's Cholesterol Level

| Results
Interventions | Lipids | Quality Considerations
Interven: immediate feedback by means of fingerstick chol check; low intensity Control: no immediate feedback on chol check | Final TC Interven: 219 mg/dl Control: 213 mg/dl Change in TC mg/dl Interven: -4 Control: -2 Net % Change: .09% p value NS | Internal Validity good External Validity fair Quality Grade fair
Interven: told if their chol was "high, not so high, or below average"; medium intensity diet intervention Control: received diet advice without knowledge of chol level | Final TC Interven: 265 mg/dl Control: 276 mg/dl Change in TC mg/dl Interven: -11 Control: 0 Net % Change: 4% p = .024 | Internal Validity fair External Validity fair Quality Grade fair
Interven: received health education and feedback on chol level; low intensity Control: internal control = subjects from a site who received neither health education nor feedback on their chol levels | Final TC Interven: 221 mg/dl Control: 224 mg/dl Change in TC mg/dl Interven: -6 Control: -1 Net % Change: 2% p = .02 | Internal Validity good External Validity fair Quality Grade fiar
Interven: received their initial chol results at the beginning of the study; medium intensity Control: received initial and final chol results at the end of the study | Final TC Interven: 186 mg/dl Control: 198 mg/dl Change in TC mg/dl Interven: -12 Control: -12 Net % Change: 0 p value NR | Internal Validity good External Validity fair Quality Grade fair

*Quasi-experimental design. Results presented here only for subects with initial cholesterol > 250. Subjects with lower initial cholesterol levels showed no effect or had small increases compared with controls.

Evidence Table 5. Dietary Interventions for Children

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
CATCH Study^177^ | Mean age: 8.76 years % F = 48.2 Setting: 3rd--5th grade elementary schools Initial TC (mg/dL): I: 169.9 (0.4) C: 170.7 (0.8) ***Total Cholesterol measured in mg/dL | Start: 5106 (total) End: 4019 | Schools were chosen based on geographic location, ethnic diversity, food service potential for intervention, commitment to offering at least 90 min/wk PE Students in 3rd grade at schools agreed to provide a blood sample at baseline | Fall 1991 -- Spring 1994
CHP/NCEP Study^240^ | I_1_: mean age (SD): 6.3 (0.2) %F: 51 TC 125.8 (1.54) I_2_: mean age (SD): 6.2 (0.2) %F: 50 TC 127.4 (1.54) C_1_: mean age (SD): 6.3 (0.2) %F: 51 TC 125.8 (1.54) C_2_: mean age (SD): 6.3 (0.2) %F: 51 TC 125.8 (1.54) Setting: 9 suburban pediatric practices | Start: 342 I_1: _88 I_2:_ 86 C_1:_ 87 C_2:_ 81 End: 292 I_1:_ 66 I_2:_ 73 C_1:_ 78 C_2:_ 75 | 3652 children between 3.3 and 9.9 years of age screened to identify those with plasma TC > 75th percentile who agreed to randomization normal controls randomly selected from children with TC < 60th percentile Exclusion: no secondary causes of increased cholesterol, body weight >85% but <130% of ideal | Oct. 1990 -- Dec. 1992 RCT with 2 nutrition education interventions and 2 control groups (1 at-risk and 1 not at-risk) Assessed at baseline, 3, 6, 12 months

Evidence Table 5. Dietary Interventions for Children

Interventions | Lipids | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
I_1_: School-based program (food service modifications, PE interventions, and classroom health curricula) I_2_: School-based program plus family-based program Control: usual health curricula, PE, and food service programs | Final TC (mg/dL): I: 168.7 C: 169.5 net % change=0 | Fat content of school lunches significant decrease Intensity of physical activity in PE class significant increase No change in blood pressure, body size, or serum TC No harmful effects of low-fat diet on growth or development | Good Internal validity: good for school level; on student level, no data on individual participation in school lunch program No mention of interaction by site; good external validity No mention of blinded assessment
I_1_: parent child autotutorial (PCAT), based on social-cognitive theory. Included 10 lessons (tapes and activities) for a 10-week period I_2_: child and at least one parent attended 45-60 min session with dietitian C_1_ & C_2_: usual care, no educational materials | I_1_: LDL decreased 4.6% - 7.9% from baseline, but not significantly different from C_1_ | I_1_ had significant increase in knowledge I_1_ & I_2_ had significant decrease in total and saturated fat intake No significant time-related differences in height, weight, or weight for height median by quintile of fat as a percentage of energy | Good/Fair Internal validity: differential dropout (15% dropout, more among intervention than control); children with and without increased TC were combined for growth analysis External validity: children with increased cholesterol, predominately white, higher SES, 89% living with both biologic parents

Evidence Table 5. Dietary Interventions for Children

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
DISC study^170,171^ | Mean age: 9.7 M 9.0 F % F: 45 Setting: children recruited from schools, HMOs, and pediatric practices Initial TC I: 200 (14.6) C: 200 (14.6) Initial HDL I: 57.1 (10.7) C: 57.0 (11.0) | Start I: 334 C:329 End I: 320 C: 303 | 44,000 children, 8--10 years of age at baseline prescreened to identify children with age & sex specific TC >75th percentile and < 99th percentile Pre-pubertal, normal psychosocial and cognitive development Exclusion: medical conditions, on medications affecting growth and/or blood lipids, family history of premature heart disease | 6-center RCT starting in 1987, running three years, with blinded assessment at baseline, year 1 & year 3

Evidence Table 5. Dietary Interventions for Children

Interventions | Lipids | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
Adherence to a diet with 28% energy from total fat, <8% saturated fat, 9% polyunsaturated fat, and <150 mg/day cholesterol Strategy based on social learning theory and social action theory: Yr1: 15 group and 4 individual meetings Yrs2 & 3: 4-6 group and individual meetings/yr with monthly phone calls Control: Usual care, given educational material available to public about heart-healthy diet. Told of increased cholesterol, no specific recommendations to see MD | Final TC I: 183.3 (21.5) C: 186.4 (22.3) % change I: 8.4% C: 6.8% Net % change 1.6%, p=0.04 Final HDL I: 52.7 (10.0) C: 52.6 (10.3) | Significant decrease in LDL in I Growth was comparable in both groups Serum ferritin decreased in both groups I (18.5%)>C (13%), but in both groups mean levels were above 75th percentile for age & sex No effect of low fat diet on puberty | Good Internal validity: Fair. Twice as many controls (8%) dropped out as intervention subjects (4%) and the two papers have opposite findings for ferritin External validity: Applies to pre-pubertal children with increased cholesterol

Evidence Table 5. Dietary Interventions for Children

Source: Author, Year | Study Population | Size of Intervention & Control Groups | Study Population Diagnosis/Condition | Study Design & Characteristics
STRIP Study^174,176^ | Age -- 5 months at enrollment %F: 49 Setting: Families recruited in well-baby clinics in Turku, Finland, at the routine 5-month visit. 56.5% of the eligible age cohort agreed to participate Initial TC: M I: 146.6 C: 149.7 F I: 162.1 C: 157.8 HDL: M I: 34.8 C: 35.2 F I: 35.2 C: 34.8 | Start: 1062 End: 816 | Healthy 5-month-old infants No discussion of exclusions | Infants enrolled between March 1990 and May 1992 at the age of 5 months; followed to age 4 years. Blood drawn at 7, 13, 24, 36 months

Evidence Table 5. Dietary Interventions for Children

Interventions | Lipids | Main Outcome & Relative Risk for Main Outcome | Quality Considerations
Counseling by nutritionist so that fat intake = 30-35% of total energy to age 3, then not exceed 30%. Tried to achieve polysaturated/monosaturated/saturated fat ratio of 1:1:1. Three or four day food records taken at 8, 13, 24, 36 months. Visits at 1-3 month intervals to age 2, then 2/yr to age 4 Controls: seen twice/year, received basic health education. Counseled to use cow''s milk with a minimum of 1.9% fat Both groups advised to use supplemental Vitamin A (400u) and Vitamin D (10u) | Final TC: M I: 159.0 C: 171.4 F I: 171.8 C: 173.3 Final HDL M I: 40.5 C: 43.2 F I: 40.5 C: 41.7 % change in TC: + 8.4% intervention + 14.7% controls 6.3% net difference | Intervention group had significant decrease in intake of fat as percentage of total energy (31.2% versus 33.1%, p<0.001) and cholesterol from age 13 months through 4 years compared to control group. Results significant only in M No adverse affects on growth in either group Both groups had low intakes of Vitamin D and iron after age 2 | Fair Internal validity: 23% dropout rate may affect internal validity. Also, the assessments were not blinded External validity: Healthy northern European infants and young children (exclusions not discussed)

Glossary of Evidence Tables Abbreviations

Abbr. | Definition
ARR | absolute risk reduction
abn | abnormal
adj | adjusted
bid | twice a day
BMI | body mass index
C | control
CHD | coronary heart disease
CHF | congestive heart failure
Chol | cholesterol
CI | confidence interval
cond | condition
CV | cardiovascular
CVA | cerebro-vascular accident
DBP | diastolic blood pressure
Diff | Difference
dL | deciliter
DM | diabetes mellitus
Dx | diagnosis
EKG | electrocardiogram
ETT | exercise treadmill test
F | female
g | grams
GI | gastrointestinal
Grps | groups
HDL | high density lipoprotein
Hg | hemoglobin
HTN | hypertension
Hx | history
I | intervention
IBW | ideal body weight
LDL | low density lipoprotein
M | male
MD | medical doctor
Meds | medications
mg | milligrams
MI | myocardial infarction
min | minute
mm | millimeter
N/A | not applicable
NNT | numbers needed to treat
NR | not reported
NS | not significant
P | probability
PE | physical education
q.d. | every day
req | required
RRR | relative risk reduction
SBP | systolic blood pressure
SD | standard deviation
SES | socioeconomic status
TC | total cholesterol
TIA | transient ischemic attack
tx | treatment
wk | week
y, yr | years

Glossary of Evidence Tables Abbreviations

Study Names | Preferred Abbreviations
Helsinki Heart Study | HHS
Air Force / Texas Coronary Prevention Study | AFCAPS/TexCAPS or TexCAPS
Children's Health Project/National Cholesterol Education Program | CHP/NCEP
Cholesterol and Recurrent Events Study | CARE
Dietary Intervention Study in Children | DISC
Lipid Research Clinics Coronary Primary Prevention Trial | LRC
Long-term Intervention with Pravastatin in Ischemic Disease | LIPID
Multi-factor Primary Prevention Trial | MRF
Multiple Risk Factor Intervention Trial Research Group | MRFIT
Oslo Study Group | Oslo
Scandivanian Simvastatin Survival Study | 4S
Special Turku Corony Risk Factor Intervention Project | STRIP
Veterans Administration High Density Lipoprotein Intervention Trial | VA HIT
West of Scotland Coronary Prevention Study | WOSCOPS
World Health Organization- European Collaborative Group | WHO