# Appendix 1 Methods

Table 1.1. Trials Excluded From Drug Therapy Literature Search*Appendix 1

Reason for Exclusion | Study
Mixed primary/secondary prevention (unable to sort out results for primary prevention population) | Dorr et al, 1978 ^29^ ; McCaughan, 1981 ^30^ ; Bradford et al, 1991 ^31^ ; Bradford et al, 1994 ^32^ ; Pravastatin Multinational Study Group, 1993 ^33^ ; Athyros et al, 1997 ^34^
Study does not measure clinical endpoints | Ives et al, 1993 ^35^ ; Lansberg et al, 1995 ^36^ ; Bredie et al, 1996 ^37^ ; Eriksson et al, 1998 ^38^
Nonrandomized study | Kyushu Lipid Intervention Study Group, 1996 ^39^ ; Itoh et al, 1997 ^40^
Drug no longer used in United States | WHO Investigators, 1978 ^41^

Thirty-four other studies (not listed) were excluded because they examined only secondary prevention.

Table 1. 2. Trials Excluded From Diet Therapy Literature SearchAppendix 1

Reason for Exclusion | Study
Inadequate (<1 year) follow-up | Luepker et al, 1978 ^42^ ; Jones et al, 1979 ^44^ ; Cunningham et al, 1987 ^45^ ; Gemson et al, 1990 ^46^ ; Kuehl et al, 1993 ^47^ ; Heller et al, 1994 ^48^ ; Rivellese et al, 1994 ^49^ ; Johnston et al, 1995 ^50^ ; Walden et al, 1997 ^51^ ; Stefanick et al, 1998 ^52^
Secondary prevention study | Andrews et al, 1997 ^53^ ; Schlierf et al, 1995 ^54^ ; La Rosa et al, 1982 ^55^ ; Kromhout, 1986 ^56^ ; Levy, 1987 ^57^ ; Heller et al, 1989 ^58^ ; Brown et al, 1990 ^59^ ; Singh et al, 1991 ^60^ ; Waters et al, 1995 ^61^ ; Niebauer et al, 1997 ^62^
No clinical endpoints | Gorder et al, 1986 ^63^ ; Lovibond et al, 1986 ^64^ ; Laitinen et al, 1993 ^65^ ; Laitinen et al, 1994 ^66^ ; Schmidt et al, 1994 ^67^ ; Bovbjerg et al, 1995 ^68^
Nonclinical setting | Cambien et al, 1981 ^69^ ; Rose et al, 1980 ^70^ ; Walter et al, 1988 ^71^ ; Schectman et al, 1994 ^72^ ; Byers et al, 1995 ^73^ ; Garcia et al, 1996 ^74^
Nonrandomized design | Murray et al, 1990 ^75^ ; Kinlay and Heller, 1990 ^76^ ; van Beurden et al, 1990 ^43^ ; Milne et al, 1994 ^77^ ; Elmer et al, 1995 ^78^
Special population | Turpeinen et al, 1979 ^79^ ; Lee-Han et al, 1988 ^80^ ; Boyd et al, 1990 ^81^ ; Insull et al., 1990 ^82^
Wrong topic/misclassified | Parker et al, 1986 ^83^ ; Johannesson et al, 1996 ^84^ ; Davidson et al, 1997 ^85^
Diet supplement trial | Anderson et al, 1992 ^86^ ; Neil et al, 1996 ^87^
Nonsystematic review or no primary data | Walsh and Grady, 1995 ^88^ ; Corr and Oliver, 1997 ^89^
Other | Dayton, 1969 ^90^